# Peer Reviewers

Jennifer L. Bailit, M.D., M.P.H.

Assistant Professor, Reproductive Biology

Department of Obstetrics & Gynecology

Case Western Reserve University—MetroHealth Medical Center

Brian Mercer, M.D.

Director, Division of Obstetrics

Director, Division of Maternal-Fetal Medicine

Case Western Reserve University—MetroHealth Medical Center

Alan M. Peaceman, M.D.

Professor, Obstetrics and Gynecology

Chief, Division of Maternal-Fetal Medicine

Feinberg School of Medicine—Northwestern Memorial Hospital

Roberto Romero, M.D.

Chief, Perinatology Research Branch

Program Director, Obstetrics and Perinatology

Wayne State University School of Medicine

Catherine Y. Spong, M.D.

Branch Chief, Pregnancy & Perinatology

National Institute of Child Health & Human Development

John M. Thorp, M.D.

Division Director; Professor

Department of Obstetrics and Gynecology

University of North Carolina School of Medicine