# Acknowledgments

We are indebted to a tireless and exceptional group of colleagues who made this report possible. Each step of a systematic review draws on the skills and attention of an entire team.

Dr. Steven Fox has been an engaged and thoughtful Task Order Officer who brought special considerations about adverse effects (harms) and key decisions about scope into focus. He provided encouragement to protect the breadth of this report and key insights for imposing structure on the synthesis of the findings in ways that will best serve those who wish to apply this evidence.

Dr. Melissa McPheeters, Associate Director of the Evidence-based Practice Center, was crucial in providing advice and in guiding review methods, including searches, data extraction, quality rating, strength-of-evidence reporting, and applicability assessment. She was especially helpful as a neutral adjudicator and as a sounding board for challenging decisions about scope and focus.

Ms. Rachel Weaver served as project coordinator, shepherding innumerable planning, implementation, and writing tasks to completion. She guided and contributed to production of the plethora of forms, spreadsheets, and tables that are required to produce reliable evidence tables and summary data. Her attentiveness to the needs of the investigator team and to pacing the work was especially valued.

Mr. Jeffrey Seroogy joined the team at a crucial time, bringing to bear his considerable organizational skills and experience with evidence report production. He worked tirelessly to format documents, check summary tables, compile quality scores, and complete critical details of the report as a whole.

Ms. Allison Glasser was always willing to contribute time and effort when having extra assistance with tasks such as printing and distributing articles was a priority and when concentration and focus were required to double and triple check data. We appreciate her generosity in helping while simultaneously managing another major report.

Ms. Cheena Clermont and Dr. Chris Slaughter provided practical assistance and expertise in documentation of all phases of the summary measures and in the conduct of the meta-analyses provided in this report. We are thankful for the involvement of staff and a biostatistics colleague who understand the value of aggregate estimates of effects of health care interventions.

Ms. Tracy Shields is a key member of the library science staff—the support she provided for Ms. Jerome, including a detailed approach to abstract and full-text review, was invaluable.