# Discussion

## State of the Literature

We identified a total of 64 publications, representing 58 distinct study populations: 7 of good quality, 38 fair, and 19, poor. Forty-six percent of the studies identified were randomized clinical trials, a smaller proportion were clinical trials without clear evidence of randomization (7%), and the balance are observational research, a number of which are analyses of administrative databases. A complete description of study characteristics is listed in Table 3 under Results (above).

## Strength of Evidence

Overall, the strength of evidence to answer the Key Questions (KQs) was insufficient to moderate, with a single exception in which evidence is moderate for lack of benefit (Table 21). Deficiencies in the strength of evidence most often related to a preponderance of study designs with high-risk of bias; inconsistent findings across studies and inconsistencies among outcomes that would be expected to show corresponding benefit; use of intermediate outcomes; and small studies with poor precision. In the summary below, we provide strength-of-evidence ratings by KQ.

Table 21 Strength of evidence for progestogens for prevention of preterm birth

Outcomes (n total RCTs; n total participants) | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Progestogen vs. placebo or no treatment for women with prior preterm birth
PTB prevention < 37 weeks (4; 1,318) | Low | Inconsistent | Direct | Fair | Moderate; effect size in meta-estimate: OR=0.66; 95% BCI: 0.53, 0.82
Mean birth weight (3; 859) | Low | Consistent | Direct | Imprecise | Moderate; weighted mean difference=239 gm; 95% CI: −44.5, 523.3 gm
Fetal/neonatal death (4; 1,318) | Mod | Inconsistent | Direct | Imprecise | Insufficient: lack of precision to estimate
Progestogen vs. placebo or no treatment in participants with threatened preterm labor
PTB prevention < 37 weeks (3; 149) | High^*^ | Inconsistent | Direct | Imprecise | Insufficient
Mean birth weight (4; 385) | High^*^ | Inconsistent | Direct | Imprecise | Insufficient; only two small trials reported birth weight
Fetal/neonatal death (1; 126) | High^*^ | Inconsistent | Direct | Imprecise | Insufficient: lack of precision to estimate
Progestogen vs. placebo or no treatment in participants with multiple gestations
PTB Prevention < 35 weeks (4; 900) | Low | Consistent | Direct | Imprecise | Moderate; effect in meta-estimate: OR=1.18; 95% BCI: 0.79, 1.39
Mean Birthweight (3; 698) | Low | Consistent | Direct | Imprecise | Moderate; no effect
Progestogen vs. placebo or no treatment in participants with multiple gestations
Fetal/Neonatal Death (5; 2,966) | High | Consistent | Direct | Imprecise | Insufficient: lack of precision to estimate
Progestogen vs. placebo or no treatment in study populations with varied risk factors
PTB prevention < 37 weeks (4; 1,194) | Mod-High | Inconsistent | Direct | Imprecise | Insufficient
Mean birth weight (2; 119) | Mod-High | Inconsistent | Direct | Imprecise | Insufficient
Fetal/neonatal death (3; 269) | High | Inconsistent | Direct | Imprecise | Insufficient: lack of precision to estimate
Progestogen vs. placebo or no treatment in studies with unique indications ^
PTB prevention < 37 weeks (1; 584) | High | NA | Direct | Imprecise | Insufficient; single study per unique indication
Mean birth weight (1; 584) | High | NA | Direct | Imprecise | Insufficient; single study per unique indication
Fetal/neonatal death (3; 1,080) | High | NA | Direct | Imprecise | Insufficient; single study per unique indication

* Average quality rating was Fair, additional deduction for sparse data, low event numbers, and non-placebo control – results in judgment of High Risk of Bias

^ Unique indications include the following: post-operative management, treatment of active-duty military personnel, abdominal surgery unrelated to pregnancy, asymptomatic short cervix.

BCI = Bayesian credible interval; CI = confidence interval; gm = grams; Mod = moderate; NA = not applicable; OR = odds ratio; PTB = preterm birth; RCT = randomized control trial.

## Principal Findings and Considerations

### KQ1 Maternal, Fetal, and Neonatal Health Outcomes

Forty-six publications, six of good quality, 28 fair, and 12 poor, using 41 study populations examined outcomes of progestogen treatment to prevent preterm birth. These 41 studies include 26 RCTs, 4 clinical trials, and 11 observational studies. This literature contains 23 unique combinations of progestogen formulation, route, and dose, making comparison across studies challenging. Furthermore, the literature contains studies focused on five groups of candidates for intervention: those with a prior preterm birth, those with symptoms of preterm labor, multiple gestations, populations with varied risk factors, and special circumstances (military service, non-obstetric abdominal surgery).

Interpretation of meta-analysis. In the Results chapter, we report the findings from meta-analysis as ORs from Bayesian models. It is important to note that when outcomes are common, such as preterm birth in these study populations, the odds ratio is not a direct surrogate for the RR. For instance, in KQ1 below consider these odds ratio and comparable approximate risk ratio pairings:

- OR=0.66 (0.53, 0.82) --> RR=0.78 (0.68, 0.90)
- OR=0.52 (0.25, 0.96) --> RR=0.53 (0.26, 0.96)
- OR=0.26 (0.10, 0.49) --> RR=0.41 (0.18, 0.66)
- OR=1.18 (0.79, 1.39) -->RR=1.09 (0.88, 1.17)

Thus the RR is somewhat smaller than it may appear from the ORs.

A total of four RCTs have focused on women with a history of preterm birth and the strength of evidence for progestogen use is low. Four RCTs provide data about gestational age at birth (< 37 weeks; for all other cutpoints fewer studies are available), three of the four demonstrate benefit (combined n=707), while a fourth (n=611) did not. In aggregate, these studies suggest reduction in risk of preterm birth (OR=0.66; 95% BCI: 0.53, 0.82) among those receiving progestogens (Figure 3). Differences in birth weight did not differ statistically across trial arms in the three studies that reported mean birth weight (239 gm; 95% CI: −44.5, 523.3 gm). Risk of neonatal death is reduced (OR=0.52; 95% BCI: 0.25, 0.96) in meta-estimates from the four trials providing data (Figure 4). All other maternal, fetal, or neonatal outcomes were reported by fewer studies or had incompatible definitions not appropriate for aggregate estimates. Findings from observational studies are inconsistent. In summary, the strength of evidence is low with documented benefit limited to reduction of births prior to 37 weeks and decreased neonatal mortality. A small number of trials have inconsistent findings; intermediate outcomes predominate; no long-term child development outcomes have been assessed; and precision for understanding rare outcomes (e.g. intraventricular hemorrhage, respiratory distress syndrome) is exceptionally poor.

Figure 3 Meta-estimate of effectiveness for preventing preterm birth (< 37 weeks) among women with prior preterm birth

Figure 3 displays a forest plot of four studies reporting the effectiveness of progestogens for preventing preterm birth before 37 weeks gestation among women with prior preterm birth. Data for Figure 3 are displayed in Table 8. Of the four RCTs represented in this forest plot, three demonstrated benefit while the fourth did not. The meta-estimates suggest reduction in risk of preterm birth (OR = 0.66; 95 percent BCI: 0.53, 0.82) among those receiving progestogens.

Figure 4 Meta-estimate of effectiveness for preventing neonatal death with maternal history of preterm birth

Figure 4 displays a forest plot of studies reporting the effectiveness of progestogens for preventing neonatal death among women with prior preterm birth. Data for Figure 4 are displayed in Table 12. Risk of neonatal death is reduced (OR = 0.52; 95 percent BCI: 0.25, 0.96) in meta-estimates from the four trials providing data. Though the 95% credible intervals of each contributing study include zero, the combined estimate excludes one.

Five RCTs used progestogens in populations of women who presented with symptoms of preterm labor (n=511). The trials include both those with documented cervical change and those with threatened preterm labor. Strength of evidence for use in this group is insufficient. Three studies, with a total of 149 participants, contributed data about gestational age using a cutpoint of 37 weeks. The meta-estimate finds the odds of preterm birth among those treated is approximately a quarter of those among controls (OR=0.26; 95% BCI: 0.10, 0.49). These trials, and related nonrandomized trials, did not collect common maternal or neonatal outcomes, rather they emphasized uterine activity and elapsed time from presentation with preterm labor to birth. Results for latency were inconsistent with two RCTs finding significant benefit and another suggesting no prolongation of time to birth. Across studies of participants with preterm labor symptoms, risk of bias is moderate to high, with inconsistent findings of which few are direct, and which lack precision.

Progestogen treatment shows no clinically significant benefit in multiple gestations. Evidence of moderate strength supports this finding. A total of three RCTs and one nonrandomized trial focused on women with twins, with only two of the RCTs (n=685) reporting preterm birth at less than 35 weeks. Two RCTs enrolled triplets (n=215). The meta-estimate for odds of preterm birth at less than 35 weeks for twins and triplets combined was 1.18 compared to those receiving placebo (95% BCI: 0.79; 1.39; Figure 5). In aggregate neonatal deaths were not reduced by treatment with a meta-estimate of OR=1.75 (95% BCI: 0.93, 2.80).

Figure 5 Meta-estimate of effectiveness for preventing preterm birth (< 35 weeks) in multiple gestations

Figure 5 displays a forest plot of four studies reporting the effectiveness of progestogens for preventing preterm birth before 35 weeks among women with multiple gestations. Two studies included women with twin pregnancies, and two studies included women with triplet pregnancies. Data for Figure 5 are presented in Table 10. The meta-estimate for odds of preterm birth at less than 35 weeks for twins and triplets combined was 1.18 compared to those receiving placebo (95 percent BCI: 0.79; 1.39).

Other outcomes also showed no benefit. Overall evidence related to multiple gestations draws on trials with low risk of bias, strong consistency, and a good grasp of neonatal outcomes, with fair precision for common outcomes like preterm birth and poor precision for more rare outcomes like neonatal death.

Among nine studies that included populations with a variety of risk factors, aggregate estimates were not appropriate. The heterogeneity of these studies combined with the lack of reporting of outcomes by indication for progestogen treatment makes it impossible to interpret their significance for specific indications. Evidence is insufficient for use of progestogens in groups broadly defined to be at high-risk of preterm birth. Of note a number of these studies combined prior preterm birth and prior spontaneous abortion within their indications.

None of the four studies that examined unique indications (post-operative management, treatment of active-duty military personnel, abdominal surgery unrelated to pregnancy, and asymptomatic short cervix) for progestogen treatment demonstrated compelling findings; all provide insufficient evidence. However, this literature continues to progress. Additional research has potential to confirm or reject indications and to further refine knowledge. For example, since completion of our systematic review an additional multisite, international randomized clinical trial94 added 458 women to the existing 250 with asymptomatic short cervix who have been studied.55 Though small and focused on birth outcomes, both trials of vaginal progesterone gel for this indication find benefit for reducing preterm birth and neonatal mortality from prematurity. This opens the way for continued research about when to conduct ultrasound screening and optimal cervical length at which to consider treatment of women with a short cervix, while also suggesting continued examination of optimal progestogens formulation55, 94

### KQ2 Harms of Progestogen Treatments

Evidence about potential harms of progestogen treatment, other than anticipated injection site discomfort, is insufficient (Table 22). Risk of bias is high because uniform ascertainment methods and operational definitions of the adverse events sought are often not described. Those harms most frequently assessed are direct effects of medication administration (injection site reactions, vaginal irritation, nausea, headache), and studies were not typically designed to investigate potential consequences of exogenous hormone exposure. Followup is short, most frequently lasting only to birth or discharge of the infant from the hospital. Prospective followup of mothers and children over years has been reported only for a small number of participants. No registry data are available that explicitly track antenatal progestogen use. Because the most concerning outcomes are also likely to be rare, it is not possible with small study sizes to determine consistency of observed risk and risk estimates have very poor precision.

Table 22 Strength of evidence related to potential harms of progestogens^*^

Outcomes (n total RCTs) | Risk of Bias | Consistency | Directness | Precision | Strength of Evidence
Complications during pregnancy
Discomfort with injection (3) | Mod | Inconsistent | Direct | Fair (common) | Moderate evidence of injection site pain as common harm; risk similar for placebo injections; related to fact of injection.
Discomfort/irritation with vaginal route (3) | High | Inconsistent | Direct | Poor | Insufficient; wide range similar to placebo, highly variable.
Gestational diabetes (2) | High | Inconsistent | Direct | Poor | Insufficient; not consistently sought in studies; wide ranges overlap with placebo.
Hypertension/PIH (5) | High | Inconsistent | Direct | Poor | Insufficient; not consistently sought in studies; wide ranges overlap with placebo.
Mode of birth and complications at birth
Cesarean (7) | High | Inconsistent | Direct | Fair | Insufficient; very wide ranges in placebo and treated; with high levels in both groups.
Chorioamnionitis (5) | High | Inconsistent | Direct | Fair | Insufficient; not consistently sought in studies; wide ranges overlap with placebo.
Postpartum bleeding complications (3) | High | Consistent | Direct | Poor | Insufficient; rare outcome; no power to assess
Neonatal complications
Neonatal infections/sepsis (8) | Mod | Inconsistent | Direct | Fair | Insufficient; overlapping ranges in placebo and treated
Neonatal deaths (16) | High | Inconsistent | Direct | Poor | Insufficient; rare outcome; no power to assess
Longer term infant/child outcomes
Congenital anomalies (8) | High | Inconsistent | Direct | Poor | Insufficient; rare outcome; no power to assess
Teratogenic effects/feminization of male infants (1) | High | NA | Direct | Poor | Insufficient; very rare outcome; no power to assess
Abnormal childhood development (1) | High | NA | Direct | Poor | Insufficient; rare outcome; no power to assess

* See Table 17 for additional detail about range of risk estimates in RCTs and other studies.

Mod = moderate; NA = not applicable; PIH = pregnancy-induced hypertension; RCT = randomized control trial.

### KQ3, KQ4, and KQ5 Modifiers of Outcomes

We sought evidence about factors that might modify treatment response in all 64 included publications. Candidate modifiers were maternal characteristics (e.g., severity of prior preterm birth, number of prior preterm births, cervical length, twins versus singletons) in KQ3. KQ4 focused on whether the formulation, route, or dose of progestogen has been shown to modify outcomes compared to another formulation, route, or dose; and KQ5 examined evidence for synergy (or antagonism) between progestogen treatment and other cointerventions. In each case, we did not identify studies that were appropriately powered to estimate the joint and separate effects of the candidate modifiers. We sought stratified analyses or those that incorporated interaction terms in multivariate models in order to apportion the contributions of the candidate modifiers.

No studies of maternal characteristics had statistical precision to assert differential benefits based on maternal characteristics. Data were not suitable for aggregation across studies. Scant data, with insufficient power, address prior preterm birth history. No data inform whether effectiveness of progestogen treatment varies among women with prior PPROM, cerclage, uterine malformation, or conceptions via assisted reproductive technology, compared to other women.

No head-to-head trials of currently available progestogens have been conducted (one 1979 trial of poor quality is the only publication); and no dose finding studies focused on efficacy or effectiveness were identified in this review. No literature addresses whether adherence or acceptability to participants varies by formulation, dose, or route. Harms data are not uniformly collected so comparisons across studies cannot provide meaningful data to inform clinical decisions. The plethora of distinct indications, inclusion and exclusion criteria, drug, dose, and route combinations virtually eliminates the ability to make indirect outcomes comparisons across studies across strata of modifiers. Indirect evidence suggests, but cannot conclusively demonstrate, that vaginal suppositories (not vaginal gels) might be as effective as 17OHP, with oral routes appearing least effective.

Meta-analysis estimates were calculated for each progestogen formulation to assess the effectiveness of an individual formulation (17OHP, oral, and vaginal progestogen) at reducing the risk for preterm birth (< 37 weeks) and neonatal mortality. This included eight 17OHP, three oral progestogen, and four vaginal progestogen RCTs.

Meta-estimates indicate that no formulation was effective at reducing risk for neonatal mortality and that all formulations were effective at reducing the risk of preterm birth (meta-estimates: OR_17OHP_=0.75, 95% BCI: 0.60 [Figure 6], OR_Vaginal_=0.76, 95% BCI: 0.57, 0.98 [Figure 7], 0.90; OR_Oral_=0.56, 95% BCI: 0.36, 0.79 [Figure 8]).

Figure 6 Meta-analysis results examining the effectiveness of intramuscular 17OHP for the prevention of preterm birth

Figure 6 displays a forest plot of studies reporting the odds ratio for the effectiveness of intramuscular 17OHP for the prevention preterm birth. Data for Figure 6 are presented on Table 18. This figure is described further in the “Discussion” section as follows: “Meta-estimates indicate that no formulation was effective at reducing risk for neonatal mortality and that all formulations were effective at reducing the risk of preterm birth (meta-estimates: OR17OHP = 0.75, 95 percent BCI: 0.60, 0.90; OROral = 0.56, 95 percent BCI: 0.36, 0.79; ORVaginal = 0.76, 95 percent BCI: 0.57, 0.98).”

Figure 7 Meta-analysis results examining the effectiveness of vaginal 17OHP for the prevention of preterm birth

Figure 7 displays a forest plot of studies of studies reporting the odds ratio for the effectiveness of vaginal 17OHP for the prevention preterm birth. Data for Figure 7 are presented on Table 19. This figure is described further in the “Discussion” section as follows: “Meta-estimates indicate that no formulation was effective at reducing risk for neonatal mortality and that all formulations were effective at reducing the risk of preterm birth (meta-estimates: OR17OHP = 0.75, 95 percent BCI: 0.60, 0.90; OROral = 0.56, 95 percent BCI: 0.36, 0.79; ORVaginal = 0.76, 95 percent BCI: 0.57, 0.98).”

Figure 8 Meta-analysis results examining the effectiveness of oral 17OHP for the prevention of preterm birth

Figure 8 displays a forest plot of studies reporting the odds ratio for the effectiveness of oral 17OHP for the prevention preterm birth. Data for Figure 8 are presented on Table 20. This figure is described further in the “Discussion” section as follows: “Meta-estimates indicate that no formulation was effective at reducing risk for neonatal mortality and that all formulations were effective at reducing the risk of preterm birth (meta-estimates: OR17OHP = 0.75, 95 percent BCI: 0.60, 0.90; OROral = 0.56, 95 percent BCI: 0.36, 0.79; ORVaginal = 0.76, 95 percent BCI: 0.57, 0.98).”

However without head-to-head comparisons it is possible that differences arise solely from populations studied or other biases. In order to make such comparisons other factors of study design would need to be fully comparable to allow isolation of the factor of interest such as formulations or cointervention and this is rarely strictly the case. The majority of the specific cointerventions were only represented once in the literature with tocolytics and tocolytics combined with another cointervention representing greater than 50 percent of the studies examining cointerventions.

Overall, no direct evidence with appropriate statistical power addresses differences in outcomes, adverse effects or safety, or adherence or acceptability based on the categories of modifiers studied in these KQs. For all modifiers evaluated evidence is insufficient to guide care. Risk of bias is high, consistency is poor or there are no relevant data, directness is lacking, and precision is poor.

### KQ6 Health System and Provider Factors

Eleven studies, five based on surveys of care providers, provide some insight into knowledge, attitudes and prescribing behavior of providers. The evidence is largely cross-sectional, from administrative data, or incidentally available from studies with other primary aims. Two surveys provided repeated measures of the same professional groups, which is not strictly equivalent to followup of the same respondents; these provide some evidence about trends in increasing use within the U.S. while remaining flat in Canada. Quality of the evidence about health system and provider factors is insufficient for understanding what factors drive decisions or modify access to intervention.

## Applicability

We used inclusion criteria intended to identify studies with applicability to women receiving prenatal care in the United States, including research from international settings with comparably advanced prenatal and neonatal care. Study populations were generally selected based on characteristics that would be feasible to duplicate in clinical care. In order to study different risk indications for treatment, for instance prior preterm birth and multiple gestations, study populations have different but appropriate approaches to inclusion and exclusion of participants. Study populations are sufficiently well-described that it is possible to extrapolate how well they represent a clinical population of interest.

This literature includes a substantial proportion of RCTs, 26 of 57 publications (46%). As in practice, there is considerable variation in progestogen formulations, doses, and intervals used for treatment. Comparators were most often comparable forms of placebos. Heterogeneity of exact interventions, combined with lack of commonality in the outcomes reported, presents challenges to combining results to develop informative aggregate estimates of effectiveness of treatment. In general, studies have been too small to provide valid estimates of factors that may exert additional influence on treatment effects such as additional maternal risk factors or cointerventions intended to create synergy to further reduce risk of preterm birth. In practice such distinctions would have value in tailoring care.

Lack of direct comparisons of treatment options further hinders ability to know what findings will best extend to a specific patient or to decisions about care protocols within clinics or health systems. An additional subtle factor is worthy of consideration in assessing whether and how findings apply to specific care populations: observed rates of spontaneous preterm births among those who did not receive intervention exceed that observed in population-level data about recurrent preterm birth. This discrepancy is not rare in research; an unknown degree and form of bias may result in selection of women who are higher risk than the larger set of women. This implies that observed absolute effects and anticipated improvements in proportion of preterm birth among those treated in practice may be greater in studies than practice. Overall the data that are available have fair to good applicability to prenatal care populations in settings within the United States and reflect interventions that could be used.

## Update on Recently Completed Research

Research about progestogens for the prevention of preterm birth remains a highly active area of investigation. After completion of this systematic review, results from a number of trials garnered attention at national meetings. We awaited publication of these reports, completing an additional update of the literature search in October 2011. Because clinical trials have the greatest potential to inform the state of the science, we restricted this update to randomized clinical trials. Eight additional trials of progestogens from prevention of preterm birth were identified (see Table 23, which supplements Table 3).

Table 23 Updated summary of progestogen interventions

Study Country Total N | Progestogen | Form | Dose & Interval | Target EGA, Start; End (weeks) | Indication
Glover et al.95 2011 U.S. N=33 | Progesterone^†^ | Oral | 400 mg qd | 16–19; 33.9 | Prior PTB
Ibrahim et al.96 2010 Egypt N=50 | 17OHP | IM | 250 mg q 7d | > 14; 36 | PTL
Sharami et al.97 2010 Iran N=173 | Progesterone | Vaginal Supp | 200 mg qd | 28–36; 36 | PTL
Chawanpaiboon et al.98 2011 Thailand N=150 | Proluton depot | IM | 250 mg q 7d | ≥ 28; 34 | PTL
Combs et al.81 2011 U.S. N=240 | 17OHP | IM | 250 mg q 7d | 16–23; 34 | Twins
Lim et al.99 2011 Netherlands N=671 | 17OHP | IM | 250 mg q 7d | 16–20; 36 | Twins
Briery et al.100 2011 U.S. N=69 | 17OHP | IM | 250 mg q 7d | ≥ 24 (98.5%); 34 | PPROM
Hassan et al.94 2011 U.S. N=458 | Progesterone | Vaginal Gel | 90 mg qd | 20–23.9; 36.9 | Short cervix

† Micronized progesterone

17OHP = 17 alpha-hydroxyprogesterone caproate; IM = intramuscular; mg = milligrams; PPROM = preterm premature rupture of membranes; PTB = preterm birth; PTL = preterm labor; qd = every day; Supp=suppository; U.S. = United States.

Four of the recently published trials were conducted outside the U.S. and four in U.S. populations. Intramuscular administration of 17OHP was studied in four trials;81, 96, 99–100 one studied intramuscular administration of Proluton depot;98 two studies used vaginal progestogens including one with gel94 and one with suppositories;97 and one trial used oral micronized progesterone.95

As organized in the table above, Table 24 below, and throughout the report, we summarize findings by the indication for use of progestogens:

Table 24 Preterm birth outcomes by indications for progestogens treatment

Author Year Study Type | Intervention (N) | Mean GA ± SD (weeks) | PTB < 37 wk (%) | PTB < 35 wk (%) | PTB ≤ 34 wk (%) | PTB ≤ 32 wk (%) | PTB ≤ 28 wk (%)
Prior Preterm Birth
Glover et al.95 2011 RCT | Oral (19) | 37.0 ± 2.7 | 26.3 | NR | NR | NR | NR
Glover et al.95 2011 RCT | Placebo (14) | 35.9 ± 3.8 | 57.1 | NR | NR | NR | NR
Preterm Labor
Ibrahim et al.96 2010 RCT | IM (25) | 37.5 ± 1.6^*^ | 32.0^*^ | NR | NR | NR | NR
Ibrahim et al.96 2010 RCT | Placebo (25) | 34.7 ± 2.5 | 52.0 | NR | NR | NR | NR
Sharami et al.97 2010 RCT | Vaginal (86) | 36.9 ± 2.3 | 41.2 | NR | 0.8 | NR | NR
Sharami et al.97 2010 RCT | Placebo (87) | 36.3 ± 1.8 | 54.2 | NR | 10.0 | NR | NR
Chawanpaiboon et al.98 2011 RCT | Proluton depot (50) | 36.9 ± 2.1 | NR | NR | NR | NR | NR
Chawanpaiboon et al.98 2011 RCT | Nifedipine (50) | 37.1 ± 1.7 | NR | NR | NR | NR | NR
Chawanpaiboon et al.98 2011 RCT | Bed rest (50) | 36.3 ± 3.0 | NR | NR | NR | NR | NR
Twin Gestation
Combs et al.81 2011 RCT | IM (160) | 35.3 ± 2.5 | 70.6 | NR | 19.4 | 9.4 | 1.9
Combs et al.81 2011 RCT | Placebo (78) | 35.9 ± 2.3 | 58.9 | NR | 14.1 | 5.1 | 1.3
Lim et al.99 2011 RCT | IM (336) | 35.4 ± 3.6 | 55.0 | NR | NR | 14.0 | 6.0
Lim et al.99 2011 RCT | Placebo (335) | 35.7 ± 3.8 | 50.0 | NR | NR | 10.0 | 5.0
Preterm Premature Rupture of Membranes
Briery et al.100 2011 RCT | IM (33) | 27.3 ± 6.9 | NR | NR | NR | NR | NR
Briery et al.100 2011 RCT | Placebo (36) | 29.5 ± 2.5 | NR | NR | NR | NR | NR
Short Cervix by Ultrasound Screening
Hassan et al.94 2011 RCT | Vaginal (235) | NR | 30.2 | 14.5^*^ | NR | NR | 5.1^*^
Hassan et al.94 2011 RCT | Placebo (223) | NR | 34.1 | 23.3 | NR | NR | 10.3

* Findings are statistically significant

GA = gestational age <weeks>; IM = intramuscular; NR = not reported; PTB = preterm birth; RCT = randomized control trial; SD = standard deviation; wk = week.

Prior preterm birth. One new study enrolled a total of 33 women with a history of preterm birth.95 The placebo group had a higher risk of preterm birth and lower gestational age compared to women in the 17OHP group. The trial was underpowered to document effectiveness. The findings are consistent with the overall literature for this indication, and this small study alone does not fundamentally change the strength of evidence for this indication which is moderate.

Preterm labor. Three trials enrolled women with preterm labor and randomly assigned participants to progesterone treatment or placebo.96–98 The smallest of these trials (N=50) of intramuscular 17OHP, conducted in Egypt, had a statistically lower proportion of preterm birth at less than 37 weeks (32% vs. 52%) and a higher mean gestational age (37.5 ± 1.6 weeks vs. 34.7 ± 2.5 weeks) than women who received placebo.96 The other two trials with 173 and 150 participants97–98 did not demonstrate effectiveness. Prematurity outcomes were comparable in the study that compared Nifedipine treatment or bedrest to Proluton. Overall these additional studies do not substantively modify strength of evidence for this indication: risk of bias is high across studies with inconsistent findings and direct evidence. While these three studies add 373 women to the total of 522 in all trials for the preterm labor indication, the inconsistency in findings suggest evidence remains insufficient with regard to whether progestogens reduce preterm birth in the context of preterm labor.

Multiple gestations. The two new trials of 17OHP in twin gestations find no benefit and observed marginally higher rates of prematurity among women receiving progestogens.81, 99 This is consistent with the assessment that there is moderate evidence of lack of benefit in multiple gestations. Indeed the addition of 911 participants in studies with consistent and direct findings is in line with moderate evidence of lack of benefit for this indication.

Preterm premature rupture of membranes (PPROM). This trial of 17-OHP among a total of 69 study participants did not find benefit in mean gestational age. Findings from this single study provide insufficient evidence.100

Short cervix. Our update identified one additional study of 458 women who had a cervical length of 10 to 20mm identified by mid-pregnancy ultrasound.94 Participants had no preterm labor symptoms and had not had cervical procedures such as conization. Those treated with vaginal progesterone gel had a significantly lower proportion of preterm birth at less than 35 weeks (14.5% vs. 23.3%) and ≤ 28 weeks (5.1% vs. 10.3%) than those in the placebo group.94 The one prior trial, enrolling 250 women also reported benefit from progesterone administered as a vaginal capsule.55 With a total of 708 participants in two trials that used different formulations, different cervical cut-points for treatment, and different outcome measures, evidence is of low strength in support of effectiveness for this indication.

## Future Research

### State of the Science

Progestogen treatment was made possible by synthesis of steroid hormones in the 1960s. The earliest trials appear in that decade, followed by relatively few contributions in the literature for the next three decades. More than half of the total body of evidence has appeared within the last decade. Observational studies have given way to RCTs, and initial data are accruing for an array of populations with different risk profiles.

Study quality is advancing, but the multiplicity of treatment targets and variations in combinations of drug, dose, and route mean that strength of evidence to inform particular clinical scenarios is limited and in many cases insufficient. Studies did not uniformly report the composition of the placebo. Use of castor oil as a placebo is a theoretical concern due to its use orally as an induction agent which causes uterine contractions. The literature contains speculative concerns101 and rebuttals102 with no definitive means of determining if castor oil as a vehicle for injected medications is itself a source of inflammatory response and harms. Direct evidence about the effects of intramuscular castor oil has not been examined in the preterm birth prevention literature.

Given continued emphasis on preventing preterm birth, and the lack of effective strategies, opportunities to expand the evidence base are likely to remain research and funding priorities. Progestogen treatment warrants continued research as a prevention strategy. Topics that would benefit from consideration include:

#### Methodologic Priorities

- Clear specifying of operational definitions for inclusion and exclusion criteria, for instance in definition of preterm labor.
- Documenting placebo formulation and biologic inactivity of the vehicle.
- Building consensus about critical maternal, fetal, neonatal, and childhood outcomes, developing a minimal core data set for future research.
- Unifying outcome definitions that facilitate aggregation of data across studies, for instance providing gestational age data for multiple cut-points or standardizing classification of neonatal morbidities like intraventricular hemorrhage.
- Ensuring adequate power to allow investigation of candidate modifiers, for instance severity of prior preterm birth and use of cointerventions, with reporting of outcomes by strata.
- Expanding use of models that allow estimation of independent and joint effects of individual risk factors and intervention.
- Developing registry or electronic medical record approaches to long-term surveillance for adverse effects.

#### Content Priorities

- Examining thresholds at which improvements in gestational age and birth weight translate to improve neonatal and childhood outcomes.
- Addressing maternal outcomes of treatment, for instance influence of hospitalization, tocolysis, and influence on risk of complications like gestational diabetes and pregnancy induced hypertension.
- Moving from surrogate outcomes closer to measures of critical health outcomes, for instance studies powered to examine neonatal survival and developmental milestones.
- Conducting comparative effectiveness trials that provide direct comparisons, for instance vaginal compared to intramuscular formulations, dose ranging studies to determine optimal effectiveness, and variation in timing of initiation and total treatment duration.
- Investigating the influence of candidate modifiers like BMI.
- Considering larger-scale studies for some indications in which there is a suggestion of potential benefit but scope of prior research is limited, for instance among women with short cervix and no evidence of preterm labor.
- Improving documentation of adherence and discontinuation of treatment with attention to reasons for discontinuation.
- Expanding the repertoire of hormonal effects that are uniformly obtained as part of surveillance for harms, for instance further investigating relationship to gestational diabetes and to teratogenic risk in infants.
- Exploring potential to identify non-responders or responders that may contribute to likelihood of benefit from progestogens.

These priorities are aligned with the research gaps identified in the 2007 Institute of Medicine report titled Preterm Birth: Causes, Consequences, and Prevention;1 and the Biomedical Research Working group of the Surgeon General’s Conference on the Prevention of Preterm Birth,103 in 2008. Continued emphasis is ensured by the 2006 United States Congress Prematurity Research Expansion and Education for Mothers who deliver Infants Early (PREEMIE) Act (P.L. 109-450),104 which includes prioritization of (1) reducing rates of preterm labor and delivery; (2) working toward an evidence-based standard of care for pregnant women at risk of preterm labor or other serious complications and for infants born preterm and at a low birthweight; and (3) reducing infant mortality and disabilities caused by prematurity.

### Current and Future Research

Recently completed and ongoing research includes the following:

Completed (4 studies):

- Two studies in women with prior preterm birth and one study each in women pregnant with twins or women with shortened cervical length
- Two studies of vaginal progesterone; one study each of oral micronized progesterone and intramuscular 17OHP

Ongoing (14 studies):

- Six studies in women with prior preterm birth; five studies in women with multiple gestations; three studies in women with shortened cervical length
- Seven studies of vaginal progesterone and five studies of intramuscular 17OHP
- Two direct comparisons of 17OHP versus vaginal progesterone

Planned (3 studies):

- Two studies in women with prior premature rupture of the membranes and one study in women with threatened preterm labor
- Two studies of intramuscular 17OHP; one study of vaginal progesterone

## Conclusions

Progestogens prevent preterm birth when used in singleton pregnancy in which the mother has had a prior spontaneous preterm birth or in which cervical length is short. The strength of the evidence supporting its use for these indications is moderate and low respectively. In contrast, moderate strength of evidence suggests lack of effectiveness for multiple gestations. Evidence is insufficient for all other uses. Across indications, data are sparse to evaluate influence on near-term outcomes like neonatal mortality and morbidities. Evidence is insufficient for understanding whether intervention has the ultimately desired outcome of preventing morbidity and promoting normal childhood development.

Many scenarios faced daily by care providers and women at risk of preterm birth and considering progestogen treatment are not informed by consistent, high-quality evidence. In this gap, use is extending into groups that lack clear evidence of benefit. Pressure to intervene is amplified by the fact that no other prevention strategies are available. Lack of large-scale, systematic evidence about potential risks, including excess risk of fetal deaths, is concerning to providers and their concern is supported by the absence of high-quality data identified. Ultimately, providing data to support choice of an optimal form of progestogen, to determine if long-term outcomes are improved, and to rule out longer term risks, will require large scale comparative effectiveness and surveillance research.