# Applicability and Quality Tables

Table 1 Key Question 1: Maternal, Fetal, and Neonatal Health Outcomes--Applicability

Domain | Description of applicability of evidence compared to question
Population | The participants in these 36 studies have a range of indications for progestogen treatment including a history of preterm birth in eight studies, preterm labor in ten studies, multiple gestation in five studies, mixed risk factors in nine studies, and unique indications (for example, abdominal surgery unrelated to pregnancy) in four studies. Eligibility criteria were generally well defined, and populations could be duplicated in clinical care. The preterm birth rate among the control group in studies of women with a history of preterm birth was frequently higher than that seen in other large-scale studies of preterm birth recurrence. Trials in which the indication for progestogen was preterm labor had wide variability how the diagnosis of threatened or actual preterm labor was made.
Intervention | The intervention was heterogeneous across studies. Overall, the 36 studies included 23 unique combinations of progestogen formulations, routes, and doses.
Comparators | The most frequent comparators were placebo treatment or no treatment. Some of the placebo treatments could have had an effect on PTB rate. Studies that used no treatment as a comparator have a risk of bias.
Outcomes | Studies commonly report preterm birth outcomes by gestational age, which is a surrogate outcome. Studies are less consistent in reporting maternal, fetal, and neonatal outcomes. Most trials are not large enough to adequately assess some critical outcomes, such as neonatal conditions associated with prematurity. Longer-term outcomes are not reported.
Setting | Studies were conducted in the United States (13), Europe (15), Asia (three), the Middle East (three), South America (one), and multiple continents (one), primarily in academic medical centers with standards of care comparable to women receiving prenatal care in the United States.

Table 2 Key Question 2: Harms of Progestogen Treatments--Applicability

Domain | Description of applicability of evidence compared to question
Population | The participants in these 50 unique populations have a range of indications for progestogen treatment including a history of preterm birth in eight studies, preterm labor in ten studies, multiple gestation in five studies, mixed risk factors in nine studies, and unique indications (for example, abdominal surgery unrelated to pregnancy) in four studies. Eligibility criteria were generally well defined, and populations could be duplicated in clinical care.
Intervention | The intervention was heterogeneous across studies and included numerous progestogen formulations, routes, and doses.
Comparators | The most frequent comparators were placebo treatment or no treatment, which are appropriate for harms assessment.
Outcomes | Studies did not consistently report harms and those that did track them were primarily conducting safety monitoring and ultimately underpowered to determine if the treatment or placebo group experienced a meaningfully disproportionate burden of adverse events. Most harms that are common, such as site pain with injections or vaginal discharge with vaginal preparations, appear to be a side effect of route and are experienced in similar high proportions across treatment and placebo groups.
Setting | Studies were conducted in the United States (27), Europe (14), Asia (4), the Middle East (1), South America (1), and multiple continents (2), in a variety of clinical settings with standards of care comparable to women receiving prenatal care in the United States.

Table 3 Key Question 3: Maternal Risk Factors as Modifiers of Outcomes--Applicability

Domain | Description of applicability of evidence compared to question
Population | Few trials included risk factor subdivision by gestational age of prior PTB. Few trials included risk factor subdivision by socioeconomic level. Trials that had data about race were not sufficiently powered to demonstrate a difference in effect based upon race. Trials that assessed degree of cervical shortening did not use a standard measure for defining short, nor did they have subdivision of the population by cervix length. Trials of patients after an episode of threatened preterm labor had much variability in gestational age at initiation, definition of preterm labor, and other cofactors.
Intervention | Oral progestogens have not been used in the USA for prevention of preterm birth. The IM progestogen may be unavailable or difficult to acquire in many communities. The vaginal progestogen must be compounded and carefully stored. Adherence may be more problematic in the real world, than in studies. There were differences in dosages and frequency of administration across studies, which would require practitioners to choose, without a head-to-head comparison to guide the choice.
Comparators | Some of the placebo treatments could have had an effect on preterm birth rate. Studies that used no treatment as a comparator have a risk of bias.
Outcomes | The critical outcomes are perinatal mortality and significant neonatal morbidity. None of the trials had sufficient power to determine if progestogens reduced these events. Heterogeneity across studies precludes combining the data. Preterm birth (determined by gestational age) and birth weight are surrogate outcomes for the critical outcomes.
Setting | The composite studies of progestogen include a wide variety of settings. Some international studies have a population that is not representative of the USA.

Table 4 Key Question 4: Type of Progestogne as Modifier of Outcomes--Applicability

Domain | Description of applicability of evidence compared to question
Population | The 43 studies had a range of indications for progestogen treatment that include history of preterm birth, preterm labor, multiple gestations, abdominal surgeries, and other risk factors for preterm birth. The majority used indicated preterm labor or history of preterm birth as the primary indication for treatment. These women received progestogen treatment using a wide range of dosages and treatments that was not consistent across studies. These studies also had a wide range of variability for the gestational age for initiation and discontinuation of treatment that were not always clearly documented in the study design.
Intervention | The progestogen intervention varied across studies. These included injected 17OHP, vaginal gels/suppositories/capsules, and oral formulations. Injected 17OHP was the most studied intervention and had the most documented literature regarding adverse effects, adherence, and outcomes for mother and infant.
Comparators | The comparison groups consisted predominately of a placebo group and/or a no treatment group. Details regarding the comparison groups were inconsistently documented across studies and often no treatment groups still included individuals who were administered tocolytics and/or received some other co-interventions such as increased access to nurses. This may introduce a bias for comparisons to the intervention group. Also, it was unclear whether the placebo used (e.g. oil injections rather than 17OHP) could have an influence on treatment outcome.
Outcomes | The primary outcomes included: gestational age at delivery, preterm birth rate as assessed through gestational age, birth weight, neonatal death, neonatal sepsis, and NICU admission. These outcomes were inconsistently reported and none of the studies had sufficient power to assess how these outcomes may have differed by gestational age at initiation/discontinuation and by treatment frequency and dosage. Few studies directly compared interventions within a single study. Few studies examined how outcomes were influenced by gestational age at initiation/discontinuation of treatment and/or frequency/dosage of the intervention.
Setting | These include studies conducted in the United States (23), Europe (13), Asia (3), Middle East (1), South America (1), and studies conducted at multiple locations (2). The settings were not homogenous across studies and direct comparisons could not be made directly to assess how this may have influenced outcomes.

Table 5 Key Question 5: Cointerventions as Modifiers of Outcomes--Applicability

Domain | Description of applicability of evidence compared to question
Population | The 18 studies that were examined for co-interventions had a range indications for progestogen treatment that include preterm labor, history of preterm birth, multiple gestations, abdominal surgeries, and other risk factor for preterm labor risk. The majority used indicated preterm labor or history of preterm birth as the primary indication for treatment. The co-interventions used were clearly indicated in most studies; however, several studies used more than one co-intervention in a single study and did not provide an informative comparison group for those analyses.
Intervention | The progestogen intervention and co-interventions varied across studies with heterogeneity in both the timing of administering the co-intervention. Primary interventions included injected micronized 17OHP, vaginal gels/suppositories, and oral progestogens. Co-interventions included: tocolytics, tocolytics and one or more co-intervention, cervical cerclage, nursing surveillance, bed rest, and “other” co-interventions.
Comparators | The comparison groups consisted predominately of a placebo group and/or a no treatment group. Informative comparisons groups for examination of co-interventions were not always provided for studies. Co-interventions were also not directly tested for in statistical analyses. Including more than one co-intervention made it unclear which con-intervention was providing a benefit.
Outcomes | The primary outcomes included: gestational age at delivery, preterm birth rate as assessed through gestational age, birth weight, neonatal death, neonatal sepsis, and NICU admission. These outcomes were inconsistently reported and none of the studies had sufficient power to assess how the co-intervention may have influenced outcome.
Setting | These include studies conducted in the United States (9), Europe (5), Asia (1), Middle East (2), and South America (1). The settings were heterogenous across studies.

Table 6 Key Question 6: Effect of Health System and Provider Factors--Applicability

Domain | Description of applicability of evidence compared to question
Population | This question encompassed two distinct populations: 1) care providers and 2) women at risk of preterm birth. In the first group, five surveys assessed provider self-report. Three were conducted in the United States with populations not consistently representative of the general population of providers. One study included providers in a clinic that participated in a 17OHP trial resulting in high knowledge and familiarity with progestogens treatment and low barriers to provision, two surveys are repeated inquiries of maternal-fetal medicine specialists, and a third was directed to a volunteer registry of obstetrician-gynecologist survey participants. The other two surveys were of complete professional groups – all obstetric care providers in Canada and all members of the Royal College in Australia and New Zealand. While the participants are expected to be a more representative, their responses indicated practice patterns differ from the US making the results of interest less informative for applying to US providers. The populations of women in the observations studies include a very small (n = 38) analysis of a Medicaid population, two analyses of women included in the Matria database, and another of a single care system. Approximately half of births in the United States are covered by Medicaid so it is an important population, however in small studies or those that draw on specialized home health resources, the experience and barriers to use may not be broadly informative.
Intervention | These studies sought to describe intervention use rather than to provide and assess an intervention. The questions and analyses are applicable to describing use of interventions in the United States.
Comparators | Studies are small or based on databases. Few analyses include comparisons or analytic models to describe differences between those who received and did not receive progesterone making the information less applicable than ideal. Provider surveys did explore factors associated with prescribing. Data from the US surveys are applicable with the caveats above.
Outcomes | Outcomes were use of progestogens. Most publications assessed provider behaviors for multiple uses that reflect real world scenarios. The databases imply a level of access to treatment and may not fully represent care in the United States.
Setting | As outlined above provider type and country in which they practiced is confounded. More generalists contributed data to surveys from outside the United States, and they have difference use patterns. In general, provider and patient data over-represent tertiary care settings and those with access to home health.

Table 7 Quality Rating of Individual Treatment Studies

Citation | Overall Quality | Randomization | Methods & masking | Pt selection criteria | Clinical setting | Participant flow diagram | Loss to followup | Drop-out rates | Power calculation | ITT | Confounding factors | Internal validity | Baseline characteristics | Intervention description | Primary Outcome | GA at Birth | Birthweight | Length of FU | Measurement methods | Measurement reliability | External validity
Bacq et al., 1997^1^ | fair | NA | NA | + | + | NA | NA | NA | − | NA | − | fair | − | − | + | + | + | − | + | + | fair
Bailit et al., 2007^2^ | poor | NA | NA | + | + | NA | NA | NA | − | NA | + | fair | − | − | − | − | − | − | + | + | poor
Berghella et al., 2010^3^ | fair | NA | NA | + | + | NA | ++ | ++ | + | + | NA | good | + | + | + | + | − | − | + | + | fair
Borna et al., 2008^4^ | fair | − | − | + | + | + | ++ | ++ | + | + | NA | fair | + | + | + | + | + | + | + | + | good
Breart et al., 1979^5^ | poor | + | − | − | + | − | + | ++ | − | − | NA | poor | − | + | + | + | + | − | + | + | fair
Briery et al., 2009^6^ | fair | + | + | + | + | − | ++ | ++ | + | + | NA | fair | − | + | + | + | + | + | + | + | good
Caritis et al., 2009^7^ | good | + | + | + | + | + | ++ | ++ | + | + | NA | good | + | + | + | + | + | + | + | + | good
Cetingoz et al., 2010^8^ | fair | + | + | + | + | + | ++ | NR | + | + | NA | good | − | + | + | + | − | − | + | + | fair
Combs et al., 2010^9^ | fair | + | + | + | + | + | ++ | + | + | + | NA | fair | − | + | + | + | + | + | + | + | fair
Corrado et al., 2002^10^ | poor | − | − | + | + | − | ++ | ++ | − | − | NA | poor | − | + | + | + | − | − | + | + | fair
Cortes-Prieto et al., 1980^11^ | fair | NA | NA | + | − | NA | NA | NA | − | NA | − | fair | − | + | + | − | + | − | + | + | fair
da Fonseca et al., 2003^12^ | fair | + | + | + | + | − | + | NR | + | − | NA | fair | + | + | + | + | − | − | + | + | fair
Dudas et al., 2006^13^ | fair | NA | NA | + | + | NA | NA | NA | − | NA | − | fair | − | − | + | + | + | ++ | + | + | fair
Durnwald et al., 2009^14^ | fair | NA | NA | + | + | NA | NA | NA | − | NA | + | fair | + | − | + | + | − | + | + | + | fair
Erny et al., 1986^15^ | poor | − | + | − | + | − | ++ | ++ | − | − | NA | poor | − | + | + | + | + | − | + | + | fair
Facchinetti et al., 2007^16^ | fair | − | − | + | + | − | ++ | ++ | + | + | NA | fair | + | + | + | + | + | + | + | + | good
Facchinetti et al., 2008^17^ | poor | + | − | + | + | − | ++ | NR | − | + | NA | poor | − | + | − | − | − | − | + | + | poor
Fonseca et al., 2007^18^ | good | + | + | + | + | + | ++ | + | + | + | NA | good | + | + | + | + | + | + | + | + | good
Fuchs & Stakemann, 1960^19^ | poor | − | + | + | + | − | NR | NR | − | − | NA | poor | − | + | + | − | + | + | + | + | fair
Gonzalez-Quintero et al., 2007^20^ | fair | NA | NA | + | + | NA | NA | NA | − | NA | − | fair | − | + | + | + | − | − | + | + | fair
Gonzalez-Quintero et al., 2010^21^ | fair | NA | NA | + | + | NA | NA | NA | + | NA | + | good | + | + | + | + | − | − | + | + | fair
Gyamfi et al., 2009^22^ | fair | + | + | + | + | − | NA | NA | − | NA | NA | fair | + | + | + | − | − | − | + | + | fair
Harper et al., 2010^23^ | fair | NA | NA | + | + | NA | ++ | ++ | − | NA | − | fair | + | + | + | + | + | + | + | + | good
Hartikainen-Sorri et al., 1980^24^ | fair | NA | NA | + | + | NA | ++ | ++ | − | NA | − | fair | − | + | + | + | − | − | + | + | fair
Hauth et al., 1983^25^ | poor | − | + | + | + | − | NR | NR | − | + | NA | poor | − | + | + | − | + | − | + | + | fair
Hill et al., 1975^26^ | poor | NA | NA | + | + | NA | NA | NA | − | NA | − | fair | − | + | + | − | − | − | + | + | poor
Hobel et al., 1994^27^ | poor | − | − | − | + | − | − | NR | + | − | NA | poor | − | + | + | + | + | − | + | + | fair
How et al., 2007^28^ | fair | NA | NA | + | + | NA | NA | NA | − | NA | − | fair | + | + | + | + | − | − | + | + | fair
Johnson et al., 1975^29^ | poor | − | + | + | + | − | + | + | − | − | NA | poor | + | + | + | + | + | − | + | + | fair
Johnson et al., 1979^30^ | poor | NA | NA | − | + | NA | − | − | − | NA | − | poor | − | + | + | + | + | − | + | + | fair
Kauppila et al., 1980^31^ | fair | NA | NA | − | + | NA | ++ | ++ | − | NA | − | fair | − | + | + | + | + | − | + | + | fair
Keeler et al., 2009^32^ | fair | + | + | + | + | + | ++ | ++ | + | + | NA | good | + | + | + | + | − | − | + | + | fair
Kester et al., 1980^33^ | poor | NA | NA | − | + | NA | NA | NA | NA | NA | − | fair | − | − | − | − | − | ++ | − | − | poor
Kester et al., 1984^34^ | poor | NA | NA | + | + | NA | NA | NA | − | NA | − | fair | − | − | + | − | − | ++ | + | + | poor
Mason et al., 2008^35^ | fair | NA | NA | + | + | NA | NA | NA | − | NA | − | fair | − | + | + | + | − | − | + | + | fair
Majhi et al., 2009^36^ | fair | + | − | + | + | + | ++ | ++ | + | + | NA | fair | + | + | + | + | + | + | + | + | good
Mason et al., 2005^37^ | poor | NA | NA | − | + | NA | NA | NA | − | NA | − | poor | − | + | + | − | − | + | + | + | fair
Mason et al., 2009^38^ | fair | NA | NA | + | + | NA | NA | NA | − | NA | + | fair | − | + | + | + | + | + | + | + | fair
Meis et al., 2003^39–43^ | fair | + | + | + | + | − | ++ | + | + | + | NA | fair | + | + | + | + | + | + | + | + | good
Meyer-Bahlburg et al., 1977; 44–45 | poor | NA | NA | + | + | NA | NA | NA | − | NA | − | fair | − | − | + | − | − | ++ | + | − | poor
Noblot et al., 1991^46^ | fair | + | + | + | + | − | ++ | ++ | − | + | NA | fair | − | + | + | + | + | − | + | + | fair
Norman et. al, 2009^47^ | fair | + | + | + | + | + | ++ | ++ | + | − | NA | fair | − | + | + | + | − | + | + | + | fair
O’Brien et al., 2007^48–50^ | good | + | + | + | + | + | ++ | ++ | + | + | NA | good | + | + | + | + | + | + | + | + | good
Øvlisen & Iversen, 1963^51^ | fair | NA | NA | + | + | NA | NA | NA | − | NA | − | fair | − | + | + | − | + | − | + | + | fair
Rai et al., 2009^52^ | fair | + | + | + | + | + | ++ | ++ | + | − | NA | fair | − | + | + | + | + | − | + | + | fair
Rebarber et al., 2007^53^ | fair | NA | NA | + | + | NA | NA | NA | − | NA | + | fair | + | + | + | + | − | − | + | + | fair
Rebarber et al., 2007^54^ | fair | NA | NA | − | + | NA | NA | NA | − | NA | + | fair | − | + | + | + | + | + | + | + | fair
Rebarber et al., 2008^55^ | fair | NA | NA | − | + | NA | NA | NA | − | NA | − | fair | − | + | + | + | − | − | + | + | fair
Reinisch & Karrow, 1977^56^ | fair | NA | NA | + | + | NA | NA | NA | − | NA | − | fair | − | + | + | − | − | ++ | + | + | fair
Resseguie et al., 1985^57^ | poor | NA | NA | + | + | NA | NA | NA | − | NA | + | fair | − | − | + | − | − | ++ | + | + | poor
Rittenberg et al., 2009^58^ | fair | NA | NA | + | + | NA | NA | NA | − | NA | − | fair | + | + | + | + | − | − | + | + | fair
Rittenberg et al., 2007^59^ | poor | NA | NA | + | + | NA | NA | NA | − | NA | NA | fair | − | + | − | + | − | − | + | + | poor
Rittenberg et al., 2008^60^ | fair | NA | NA | + | + | NA | NA | NA | − | NA | − | fair | + | + | − | + | − | − | + | + | fair
Rouse et al., 2007^61^ | good | + | + | + | + | + | ++ | ++ | + | + | NA | good | + | + | + | + | + | + | + | + | good
Suvonnakote, 1986^62^ | poor | NA | NA | − | + | − | ++ | ++ | − | NA | NA | poor | − | + | + | + | + | − | + | + | fair
Szekeres-Bartho et al., 1983^63^ | fair | NA | NA | + | + | NA | NA | NA | − | NA | − | fair | − | + | + | + | + | − | + | + | fair
Ventolini et al., 2008^64^ | fair | NA | NA | + | + | NA | NA | NA | − | NA | − | fair | + | + | + | + | − | − | + | + | fair
Yemini et al., 1985^65^ | fair | − | − | + | + | − | + | ++ | − | + | NA | poor | + | + | + | + | + | + | + | + | good

Table 8 Quality Rating of Individual Studies of Surveys

Citation | Description of Sampling (+/−) | Number Sampled (+/−) | Number Eligible (+/−) | Number of respondents (+/−) | Response rate: ≥50 = ++ ≥33 = + <33 or NR= − | Description of Respondents (+/−) | Overall Quality
Ness et al., 2006^66^ | 1 | 1 | 1 | 1 | 1 | −1 | Fair
Dodd et al., 2007^67^ | 1 | 1 | 1 | 1 | 2 | 1 | Good
Hui et al., 2007^68^ | 1 | 1 | 1 | 1 | 1 | 1 | Fair
Ness et al., 2006^69^ | 1 | 1 | 1 | 1 | 1 | 1 | Fair
Henderson et al., 2009^70^ | 1 | 1 | 1 | 1 | 2 | 1 | Good

## References

1 Bacq Y, Sapey T, Brechot MC, et al. Intrahepatic cholestasis of pregnancy: a French prospective study. Hepatology. Aug. 1997;26(2):358-64. [pmid: 9252146].
2 Bailit JL, Berkowitz R, Thorp JM, et al. Use of progesterone to prevent preterm birth at a tertiary care center. J Reprod Med. Apr. 2007;52(4):280-4. [pmid: 17506366].
3 Berghella V, Figueroa D, Szychowski JM, et al. 17-alpha-hydroxyprogesterone caproate for the prevention of preterm birth in women with prior preterm birth and a short cervical length. Am J Obstet Gynecol. Apr. 2010;202(4):351 e1-6. [pmid: 20350641].
4 Borna S, Sahabi N. Progesterone for maintenance tocolytic therapy after threatened preterm labour: a randomised controlled trial. Aust N Z J Obstet Gynaecol. Feb. 2008;48(1):58-63. [pmid: 18275573].
5 Breart G, Lanfranchi M, Chavigny C, et al. A comparative study of the efficiency of hydroxyprogesterone caproate and of chlormadinone acetate in the prevention of premature labor. Int J Gynaecol Obstet. Mar–Apr. 1979;16(5):381-4. [pmid: 86468].
6 Briery CM, Veillon EW, Klauser CK, et al. Progesterone does not prevent preterm births in women with twins. South Med J. Sep. 2009;102(9):900-4. [pmid: 19668021].
7 Caritis SN, Rouse DJ, Peaceman AM, et al. Prevention of preterm birth in triplets using 17 alpha-hydroxyprogesterone caproate: a randomized controlled trial. Obstet Gynecol. Feb. 2009;113(2 Pt 1):285-92. [pmid: 19155896].
8 Cetingoz E, Cam C, Sakalli M, et al. Progesterone effects on preterm birth in high-risk pregnancies: a randomized placebo-controlled trial. Arch Gynecol Obstet. 2010. Jan. 22.
9 Combs CA, Garite T, Maurel K, et al. Failure of 17-hydroxyprogesterone to reduce neonatal morbidity or prolong triplet pregnancy: a double-blind, randomized clinical trial. Am J Obstet Gynecol. Sep. 2010;203(3):248 e1-9. [pmid: 20816146].
10 Corrado F, Dugo C, Cannata ML, et al. A randomised trial of progesterone prophylaxis after midtrimester amniocentesis. Eur J Obstet Gynecol Reprod Biol. Jan. 10. 2002;100(2):196-8. [pmid: 11750964].
11 Cortes-Prieto J, Bosch AO, Rocha JA. Allylestrenol: three years of experience with Gestanon in threatened abortion and premature labor. Clin Ther. 1980;3(3):200-8. [pmid: 7459930].
12 da Fonseca EB, Bittar RE, Carvalho MH, et al. Prophylactic administration of progesterone by vaginal suppository to reduce the incidence of spontaneous preterm birth in women at increased risk: a randomized placebo-controlled double-blind study. Am J Obstet Gynecol. Feb. 2003;188(2):419-24. [pmid: 12592250].
13 Dudas I, Gidai J, Czeizel AE. Population-based case-control teratogenic study of hydroxyprogesterone treatment during pregnancy. Congenit Anom (Kyoto). Dec. 2006;46(4):194-8. [pmid: 17096820].
14 Durnwald CP, Lynch CD, Walker H, et al. The effect of treatment with 17 alpha-hydroxyprogesterone caproate on changes in cervical length over time. Am J Obstet Gynecol. Oct. 2009;201(4):410 e1-5. [pmid: 19716117].
15 Erny R, Pigne A, Prouvost C, et al. The effects of oral administration of progesterone for premature labor. Am J Obstet Gynecol. Mar. 1986;154(3):525-9. [pmid: 3513581].
16 Facchinetti F, Paganelli S, Comitini G, et al. Cervical length changes during preterm cervical ripening: effects of 17-alpha-hydroxyprogesterone caproate. Am J Obstet Gynecol. May. 2007;196(5):453 e1-4. discussion 421. [pmid: 17466698].
17 Facchinetti F, Dante G, Venturini P, et al. 17alpha-hydroxy-progesterone effects on cervical proinflammatory agents in women at risk for preterm delivery. Am J Perinatol. Sep. 2008;25(8):503-6. [pmid: 18756431].
18 Fonseca EB, Celik E, Parra M, et al. Progesterone and the risk of preterm birth among women with a short cervix. N Engl J Med. Aug. 2. 2007;357(5):462-9. [pmid: 17671254].
19 Fuchs F, Stakemann G. Treatment of threatened premature labor with large doses of progesterone. Am J Obstet Gynecol. Jan. 1960;79:172-6. [pmid: 13825506].
20 Gonzalez-Quintero VH, Istwan NB, Rhea DJ, et al. Gestational age at initiation of 17-hydroxyprogesterone caproate (17P) and recurrent preterm delivery. J Matern Fetal Neonatal Med. Mar. 2007;20(3):249-52. [pmid: 17437227].
21 Gonzalez-Quintero VH, de la Torre L, Rhea DJ, et al. Impact of prior gestational age at preterm delivery on effectiveness of 17-alpha-hydroxyprogesterone caproate in practice. Am J Obstet Gynecol. Sep. 2010;203(3):257 e1-5. [pmid: 20678745].
22 Gyamfi C, Horton AL, Momirova V, et al. The effect of 17-alpha hydroxyprogesterone caproate on the risk of gestational diabetes in singleton or twin pregnancies. Am J Obstet Gynecol. Oct. 2009;201(4):392 e1-5. [pmid: 19716543].
23 Harper M, Thom E, Klebanoff MA, et al. Omega-3 fatty acid supplementation to prevent recurrent preterm birth: a randomized controlled trial. Obstet Gynecol. Feb. 2010;115(2 Pt 1):234-42. [pmid: 20093894].
24 Hartikainen-Sorri AL, Kauppila A, Tuimala R. Inefficacy of 17 alpha-hydroxyprogesterone caproate in the prevention of prematurity in twin pregnancy. Obstet Gynecol. Dec. 1980;56(6):692-5. [pmid: 7443111].
25 Hauth JC, Gilstrap LC 3rd, Brekken AL, et al. The effect of 17 alpha-hydroxyprogesterone caproate on pregnancy outcome in an active-duty military population. Am J Obstet Gynecol. May. 15. 1983;146(2):187-90. [pmid: 6682631].
26 Hill LM, Johnson CE, Lee RA. Prophylactic use of hydroxyprogesterone caproate in abdominal surgery during pregnancy. A retrospective evaluation. Obstet Gynecol. Sep. 1975;46(3):287-90. [pmid: 1161231].
27 Hobel CJ, Ross MG, Bemis RL, et al. The West Los Angeles Preterm Birth Prevention Project. I. Program impact on high-risk women. Am J Obstet Gynecol. Jan. 1994;170(1 Pt 1):54-62. [pmid: 8296845].
28 How HY, Barton JR, Istwan NB, et al. Prophylaxis with 17 alpha-hydroxyprogesterone caproate for prevention of recurrent preterm delivery: does gestational age at initiation of treatment matter?. Am J Obstet Gynecol. Sep. 2007;197(3):260 e1-4. [pmid: 17826411].
29 Johnson JW, Austin KL, Jones GS, et al. Efficacy of 17alpha-hydroxyprogesterone caproate in the prevention of premature labor. N Engl J Med. Oct. 2. 1975;293(14):675-80. [pmid: 1099445].
30 Johnson JW, Lee PA, Zachary AS, et al. High-risk prematurity--progestin treatment and steroid studies. Obstet Gynecol. Oct. 1979;54(4):412-8. [pmid: 492618].
31 Kauppila A, Hartikainen-Sorri AL, Janne O, et al. Suppression of threatened premature labor by administration of cortisol and 17 alpha-hydroxyprogesterone caproate: a comparison with ritodrine. Am J Obstet Gynecol. Oct. 15. 1980;138(4):404-8. [pmid: 7424996].
32 Keeler SM, Kiefer D, Rochon M, et al. A randomized trial of cerclage vs. 17 alpha-hydroxyprogesterone caproate for treatment of short cervix. J Perinat Med. 2009;37(5):473-9. [pmid: 19492920].
33 Kester P, Green R, Finch SJ, et al. Prenatal 'female hormone' administration and psychosexual development in human males. Psychoneuroendocrinology. Dec. 1980;5(4):269-85. [pmid: 7208750].
34 Kester PA. Effects of prenatally administered 17 alpha-hydroxyprogesterone caproate on adolescent males. Arch Sex Behav. Oct. 1984;13(5):441-55. [pmid: 6517685].
35 Mason MV, House KM, Linehan J, et al. Optimizing the use of 17P in pregnant managed Medicaid members. Manag Care. Jan. 2008;17(1):47-52. [pmid: 18274315].
36 Majhi P, Bagga R, Kalra J, et al. Intravaginal use of natural micronised progesterone to prevent pre-term birth: a randomised trial in India. J Obstet Gynaecol. Aug. 2009;29(6):493-8. [pmid: 19697195].
37 Mason MV, House KM, Fuest CM, et al. 17 alpha-hydroxyprogesterone caproate (17P) usage in a Medicaid managed care plan and reduction in neonatal intensive care unit days. Manag Care. Oct. 2005;14(10):58-63. [pmid: 16277194].
38 Mason MV, Poole-Yaeger A, Krueger CR, et al. Impact of 17P usage on NICU admissions in a managed medicaid population--a five-year review. Manag Care. Feb. 2010;19(2):46-52. [pmid: 20550052].
39 Meis PJ, Klebanoff M, Thom E, et al. Prevention of recurrent preterm delivery by 17 alpha-hydroxyprogesterone caproate. N Engl J Med. Jun. 12. 2003;348(24):2379-85. [pmid: 12802023].
40 Klebanoff MA, Meis PJ, Dombrowski MP, et al. Salivary progesterone and estriol among pregnant women treated with 17-alpha-hydroxyprogesterone caproate or placebo. Am J Obstet Gynecol. Nov. 2008;199(5):506 e1-7. [pmid: 18456237].
41 Northen AT, Norman GS, Anderson K, et al. Follow-up of children exposed in utero to 17 alpha-hydroxyprogesterone caproate compared with placebo. Obstet Gynecol. Oct. 2007;110(4):865-72. [pmid: 17906021].
42 Meis PJ, Klebanoff M, Dombrowski MP, et al. Does progesterone treatment influence risk factors for recurrent preterm delivery?. Obstet Gynecol. Sep. 2005;106(3):557-61. [pmid: 16135587].
43 Spong CY, Meis PJ, Thom EA, et al. Progesterone for prevention of recurrent preterm birth: impact of gestational age at previous delivery. Am J Obstet Gynecol. Sep. 2005;193(3 Pt 2):1127-31. [pmid: 16157124].
44 Meyer Bahlburg HF, Grisanti GC, Ehrhardt AA. Prenatal effects of sex hormones on human male behavior: medroxyprogesterone acetate (MPA). Psychoneuroendocrinology. Oct. 1977;2(4):383-90. [pmid: 564072].
45 Ehrhardt AA, Grisanti GC, Meyer-Bahlburg HF. Prenatal exposure to medroxyprogesterone acetate (MPA) in girls. Psychoneuroendocrinology. Oct. 1977;2(4):391-8. [pmid: 601176].
46 Noblot G, Audra P, Dargent D, et al. The use of micronized progesterone in the treatment of menace of preterm delivery. Eur J Obstet Gynecol Reprod Biol. Jul. 25. 1991;40(3):203-9. [pmid: 1879595].
47 Norman JE, Mackenzie F, Owen P, et al. Progesterone for the prevention of preterm birth in twin pregnancy (STOPPIT): a randomised, double-blind, placebo-controlled study and meta-analysis. Lancet. Jun. 13. 2009;373(9680):2034-40. [pmid: 19523680].
48 O'Brien JM, Adair CD, Lewis DF, et al. Progesterone vaginal gel for the reduction of recurrent preterm birth: primary results from a randomized, double-blind, placebo-controlled trial. Ultrasound Obstet Gynecol. Oct. 2007;30(5):687-96. [pmid: 17899572].
49 DeFranco EA, O'Brien JM, Adair CD, et al. Vaginal progesterone is associated with a decrease in risk for early preterm birth and improved neonatal outcome in women with a short cervix: a secondary analysis from a randomized, double-blind, placebo-controlled trial. Ultrasound Obstet Gynecol. Oct. 2007;30(5):697-705. [pmid: 17899571].
50 O'Brien JM, Defranco EA, Adair CD, et al. Effect of progesterone on cervical shortening in women at risk for preterm birth: secondary analysis from a multinational, randomized, double-blind, placebo-controlled trial. Ultrasound Obstet Gynecol. Dec. 2009;34(6):653-9. [pmid: 19918965].
51 Ovlisen B, Iversen J. Treatment of threatened premature labor with 6alpha-methyl-17alpha-acetoxyprogesterone. Am J Obstet Gynecol. Jun. 1. 1963;86:291-5. [pmid: 13940818].
52 Rai P, Rajaram S, Goel N, et al. Oral micronized progesterone for prevention of preterm birth. Int J Gynaecol Obstet. Jan. 2009;104(1):40-3. [pmid: 18929360].
53 Rebarber A, Istwan NB, Russo-Stieglitz K, et al. Increased incidence of gestational diabetes in women receiving prophylactic 17alpha-hydroxyprogesterone caproate for prevention of recurrent preterm delivery. Diabetes Care. Sep. 2007;30(9):2277-80. [pmid: 17563346].
54 Rebarber A, Ferrara LA, Hanley ML, et al. Increased recurrence of preterm delivery with early cessation of 17-alpha-hydroxyprogesterone caproate. Am J Obstet Gynecol. Mar. 2007;196(3):224 e1-4. [pmid: 17346529].
55 Rebarber A, Cleary-Goldman J, Istwan NB, et al. The use of 17 alpha-hydroxyprogesterone caproate (17p) in women with cervical cerclage. Am J Perinatol. May. 2008;25(5):271-5. [pmid: 18401840].
56 Reinisch JM, Karow WG. Prenatal exposure to synthetic progestins and estrogens: effects on human development. Arch Sex Behav. Jul. 1977;6(4):257-88. [pmid: 889431].
57 Resseguie LJ, Hick JF, Bruen JA, et al. Congenital malformations among offspring exposed in utero to progestins, Olmsted County, Minnesota, 1936–1974. Fertil Steril. Apr. 1985;43(4):514-9. [pmid: 3987922].
58 Rittenberg C, Newman RB, Istwan NB, et al. Preterm birth prevention by 17 alpha-hydroxyprogesterone caproate vs. daily nursing surveillance. J Reprod Med. Feb. 2009;54(2):47-52. [pmid: 19301566].
59 Rittenberg C, Sullivan S, Istwan N, et al. Clinical characteristics of women prescribed 17 alpha-hydroxyprogesterone caproate in the community setting. Am J Obstet Gynecol. Sep. 2007;197(3):262 e1-4. [pmid: 17826412].
60 Rittenberg C, Sullivan S, Istwan N, et al. Women receiving 17-alpha-hydroxyprogesterone caproate hospitalized for preterm labor at less than 34 weeks benefit from daily perinatal nursing surveillance. Am J Obstet Gynecol. Oct. 2008;199(4):389 e1-4. [pmid: 18928983].
61 Rouse DJ, Caritis SN, Peaceman AM, et al. A trial of 17 alpha-hydroxyprogesterone caproate to prevent prematurity in twins. N Engl J Med. Aug. 2. 2007;357(5):454-61. [pmid: 17671253].
62 Suvonnakote T. Prevention of pre-term labour with progesterone. J Med Assoc Thai. Oct. 1986;69(10):538-42. [pmid: 3819611].
63 Szekeres-Bartho J, Csernus V, Hadnagy J, et al. Influence of treatment with prostaglandin synthesis inhibitor or progesterone on cytotoxic activity and progesterone binding capacity of lymphocytes during pregnancy. Prostaglandins. Aug. 1983;26(2):187-95. [pmid: 6647870].
64 Ventolini G, Duke J, Po W, et al. The impact of maternal body mass on the effectiveness of 17 alpha-hydroxyprogesterone caproate. J Reprod Med. Sep. 2008;53(9):667-71. [pmid: 18839818].
65 Yemini M, Borenstein R, Dreazen E, et al. Prevention of premature labor by 17 alpha-hydroxyprogesterone caproate. Am J Obstet Gynecol. Mar. 1. 1985;151(5):574-7. [pmid: 3976757].
66 Ness A, Baxter J, Hyslop T, et al. Progesterone for preventing premature birth: practice patterns of board-certified maternal-fetal medicine specialists in the United States. J Reprod Med. May. 2006;51(5):411-5. [pmid: 16779989].
67 Dodd JM, Ashwood P, Flenady V, et al. A survey of clinician and patient attitudes towards the use of progesterone for women at risk of preterm birth. Aust N Z J Obstet Gynaecol. Apr. 2007;47(2):106-9. [pmid: 17355298].
68 Hui D, Liu G, Kavuma E, et al. Preterm labour and birth: a survey of clinical practice regarding use of tocolytics, antenatal corticosteroids, and progesterone. J Obstet Gynaecol Can. Feb. 2007;29(2):117-30. [pmid: 17346482].
69 Ness A, Dias T, Damus K, et al. Impact of the recent randomized trials on the use of progesterone to prevent preterm birth: a 2005 follow-up survey. Am J Obstet Gynecol. Oct. 2006;195(4):1174-9. [pmid: 17000251].
70 Henderson ZT, Power ML, Berghella V, et al. Attitudes and practices regarding use of progesterone to prevent preterm births. Am J Perinatol. Aug. 2009;26(7):529-36. [pmid: 19301227].