# Evidence Tables

Tables are sorted by last name of first author.

Evidence Table D-1 Progestogens for Prevention of PTB