# Sample Data Extraction Forms

Abstract Review Form

Full-text Review Form