# Reference List of Excluded Studies

Article Exclusion Criteria Codes for Database

X-1: Not original research

X-2: Ineligible study size

X-3: Not related to the use of progestogens to prevent PTB

X-4: Did not address study questions

Arresting premature labour: orciprenaline and other drugs. Drug Ther Bull. Mar. 30. 1973;11(7):25-7. X-1, X-2, X-4. [pmid: 4580877].
Editorial: The initiation of labour. Lancet. Jan. 26. 1974;1(7848):124-5. X-1. [pmid: 4130316].
ACOG Committee Opinion. Use of progesterone to reduce preterm birth. Obstet Gynecol. Nov. 2003;102(5 Pt 1):1115-6. X-1. [pmid: 14672496].
Use of progesterone to reduce preterm birth. Int J Gynaecol Obstet. Jan. 2004;84(1):93-4. X-1, X-2, X-4. [pmid: 14959752].
ACOG Committee Opinion number 419 October 2008 (replaces no. 291, November 2003). Use of progesterone to reduce preterm birth. Obstet Gynecol. Oct. 2008;112(4):963-5. X-1. [pmid: 18827143].
Abu-Hayyeh S, Martinez-Becerra P, Sheikh Abdul, Kadir SH, et al. Inhibition of Na+-taurocholate Co-transporting polypeptide-mediated bile acid transport by cholestatic sulfated progesterone metabolites. J Biol Chem. May. 28. 2010;285(22):16504-12. X-3. [pmid: 20177056].
Acs N, Banhidy F, Puho EH, et al. No association between vulvovaginitis-bacterial vaginosis, related drug treatments of pregnant women, and congenital abnormalities in their offspring - A population-based case-control study. Central European Journal of Medicine. 2008;3(3):332-340. X-3, X-4.
al-Nuaim AR, Abdullah MA, Stevens B, et al. Effect of gender, birth weight and gestational age on serum 17-hydroxyprogesterone concentration and distribution among neonates in Saudi Arabia. Indian J Pediatr. Sep-Oct. 62. 1995;(5):605-9. X-3. [pmid: 10829930].
Amory J, Lawler R, Shields L. Hydroxyprogesterone caproate and progesterone increase tumor necrosis factor-alpha production in lipopolysaccharide stimulated whole blood from non-pregnant women. J Perinat Med. 2005;33(6):506-9. X-2, X-3. [pmid: 16318612].
Anderson BL, Nau GJ, Simhan HN. Idiopathic vertebral abscess in pregnancy: case report and literature review. Am J Perinatol. Jun. 2007;24(6):377-9. X-2. [pmid: 17566949].
Anderson L, Martin W, Higgins C, et al. The effect of progesterone on myometrial contractility, potassium channels, and tocolytic efficacy. Reprod Sci. Nov. 2009;16(11):1052-61. X-3. [pmid: 19602723].
Antinori S, Gholami GH, Versaci C, et al. Obstetric and prenatal outcome in menopausal women: a 12-year clinical study. Reprod Biomed Online. Mar. 2003;6(2):257-61. X-3. [pmid: 12676011].
Anumba DO. Management of women with a previous preterm birth. Obstetrics, Gynaecology and Reproductive Medicine. Jun. 2007;17(6):188-191. X-1, X-2.
Attardi BJ, Zeleznik A, Simhan H, et al. Comparison of progesterone and glucocorticoid receptor binding and stimulation of gene expression by progesterone, 17-alpha hydroxyprogesterone caproate, and related progestins. Am J Obstet Gynecol. Dec. 2007;197(6):599 e1-7. X-3. [pmid: 18060946].
Aubry RH, Nesbitt RE Jr. High-risk obstetrics. 3. Cytohormonal evaluations and their practical utility in managing high-risk patients. Am J Obstet Gynecol. May. 1. 1970;107(1):48-64. X-3, X-4. [pmid: 5443064].
Aubry RH, Nesbitt RE Jr. High-risk obstetrics. V. Cytohormonal and interhormonal relationships in normal and abnormal pregnancy. Am J Obstet Gynecol. Aug. 1. 1970;107(7):990-1001. X-3, X-4. [pmid: 5429980].
Aufdenblatten M, Baumann M, Raio L, et al. Prematurity is related to high placental cortisol in preeclampsia. Pediatr Res. Feb. 2009;65(2):198-202. X-3. [pmid: 19047954].
Banhidy F, Acs N, Horvath-Puho E, et al. Pregnancy complications and delivery outcomes in pregnant women with severe migraine. European Journal of Obstetrics Gynecology and Reproductive Biology. 2007;134(2):157-163. X-3.
Bauminger S, Atad J, Feuchtwanger S, et al. Hormonal profile during termination of midtrimester pregnancy by extraovular instillation of saline: plasma levels of prostaglandins, progesterone and human chorionic gonadotropin. Prostaglandins Leukot Med. Jan. 1982;8(1):83-92. X-2, X-3. [pmid: 6952279].
Beard CM, Melton LJ 3rd, O’Fallon WM, et al. Cryptorchism and maternal estrogen exposure. Am J Epidemiol. Nov. 1984;120(5):707-16. X-3,. [pmid: 6149686].
Behrman SJ. On reducing prematurity: the hospital’s role. Hosp Pract (Hosp Ed). Jun. 1982;17(6):15-6. X-1. [pmid: 6125465].
Bell R. Antenatal oestradiol and progesterone concentrations in patients subsequently having preterm labour. Br J Obstet Gynaecol. Oct. 1983;90(10):888-91. X-3. [pmid: 6626488].
Bengtsson LP, Siener H. Experiments on the inhibition of uterine motility in premature labour. Bibl Gynaecol. 1966;42:79-92. X-2. [pmid: 5963880].
Bibby JG, Higgs SA, Kent AP, et al. Plasma steroid changes in pre-term labour in association with salbutamol infusion. Br J Obstet Gynaecol. Jun. 1978;85(6):425-30. X-3. [pmid: 656346].
Block BS, Liggins GC, Creasy RK. Preterm delivery is not predicted by serial plasma estradiol or progesterone concentration measurements. Am J Obstet Gynecol. Nov. 15. 1984;150(6):716-22. X-3. [pmid: 6496593].
Bolt RJ, van Weissenbruch MM, Popp-Snijders C, et al. Fetal growth and the function of the adrenal cortex in preterm infants. J Clin Endocrinol Metab. Mar. 2002;87(3):1194-9. X-2, X-3. [pmid: 11889187].
Bolt RJ, Van Weissenbruch MM, Popp-Snijders C, et al. Maturity of the adrenal cortex in very preterm infants is related to gestational age. Pediatr Res. Sep. 2002;52(3):405-10. X-2, X-3. [pmid: 12193676].
Borrero C, Remohi J, Ord T, et al. A program of oocyte donation and gamete intra-fallopian transfer. Hum Reprod. Apr. 1989;4(3):275-9. X-2, X-3. [pmid: 2715301].
Boulot P, Hedon B, Pelliccia G, et al. Favourable outcome in 33 triplet pregnancies managed between 1985–1990. Eur J Obstet Gynecol Reprod Biol. Jan. 31. 1992;43(2):123-9. X-4. [pmid: 1563559].
Brancazio LR, Murtha AP, Heine RP. Prevention of recurrent preterm delivery by 17 alpha-hydroxyprogesterone caproate. N Engl J Med. Sep. 11. 2003;349(11):1087-8. author reply 1087–8. X-1, X-2. [pmid: 12968095].
Branisteanu DD, Mathieu C. Progesterone in gestational diabetes mellitus: guilty or not guilty?. Trends Endocrinol Metab. Mar. 2003;14(2):54-6. X-1, X-2. [pmid: 12591170].
Brenner WE, Hendricks CH. Effect of medroxyprogesterone acetate upon the duration and characteristics of human gestation and labor. Am J Obstet Gynecol. Apr. 15. 1962;83:1094-8. X-3, X-4. [pmid: 13872839].
Brent RL. Nongenital malformations following exposure to progestational drugs: the last chapter of an erroneous allegation. Birth Defects Res A Clin Mol Teratol. Nov. 2005;73(11):906-18. X-1, X-3. [pmid: 16206282].
Brost BC, Newman RB, Hendricks SK, et al. Effect of hemodialysis on serum progesterone level in pregnant women. Am J Kidney Dis. May. 1999;33(5):917-9. X-2, X-3. [pmid: 10213649].
Buyukkayhan D, Ozturk MA, Kurtoglu S, et al. Effect of antenatal betamethasone use on adrenal gland size and endogenous cortisol and 17-hydroxyprogesterone in preterm neonates. J Pediatr Endocrinol Metab. Nov. 2009;22(11):1027-31. X-3. [pmid: 20101888].
Cahill AG, Odibo AO, Caughey AB, et al. Universal cervical length screening and treatment with vaginal progesterone to prevent preterm birth: a decision and economic analysis. Am J Obstet Gynecol. Jun. 2010;202(6):548 e1-8. X-3. [pmid: 20079888].
Cakmak H, Schatz F, Huang ST, et al. Progestin suppresses thrombin- and interleukin-1beta-induced interleukin-11 production in term decidual cells: implications for preterm delivery. J Clin Endocrinol Metab. Sep. 2005;90(9):5279-86. X-3. [pmid: 15998775].
Calda P. Safety signals of 17-OHP-C use in pregnancy and efficacy in the prevention of preterm birth. J Matern Fetal Neonatal Med. Jun. 2009;22(6):540-2. X-1, X-2, X-4. [pmid: 19089768].
Callejo J, Salvador C, Eduardo Gonzalez B, et al. Treatment of early menopause in women who whish to become pregnant. Revista de Iberoamericana de Revisiones en Menopausia. 2001;3(2):19-21. X-1, X-2, X-3.
Caritis SN, Hirsch RP, Zeleznik AJ. Adrenergic stimulation of placental progesterone production. J Clin Endocrinol Metab. May. 1983;56(5):969-72. X-2, X-3. [pmid: 6300180].
Carmichael SL, Abrams B. A critical review of the relationship between gestational weight gain and preterm delivery. Obstet Gynecol. May. 1997;89(5 Pt 2):865-73. X-1, X-3. [pmid: 9166359].
Carmichael SL, Shaw GM, Laurent C, et al. Maternal progestin intake and risk of hypospadias. Arch Pediatr Adolesc Med. Oct. 2005;159(10):957-62. X-3. [pmid: 16203941].
Casey ML, MacDonald PC. Endocrinology of preterm birth. Clin Obstet Gynecol. Sep. 1984;27(3):562-71. X-1, X-2, X-3, X-4. [pmid: 6488605].
Cavarzere P, Camilot M, Teofoli F, et al. Neonatal screening for congenital adrenal hyperplasia in North-Eastern Italy: a report three years into the program. Horm Res. 2005;63(4):180-6. X-2, X-3. [pmid: 15818055].
Cavarzere P, Samara-Boustani D, Flechtner I, et al. Transient hyper-17-hydroxyprogesteronemia: a clinical subgroup of patients diagnosed at neonatal screening for congenital adrenal hyperplasia. Eur J Endocrinol. Aug. 2009;161(2):285-92. X-2, X-3. [pmid: 19451212].
Challis JRG, Matthews SG, Gibb W, et al. Endocrine and paracrine regulation of birth at term and preterm. Endocr Rev. Oct. 2000;21(5):514-50. X-2, X-3. [pmid: 11041447].
Chandiramani M, Tribe RM, Shennan AH. Preterm labour and prematurity. Obstetrics. Gynaecology and Reproductive Medicine. 2007;17(8):232-237. X-1, X-2.
Chanrachakul B, Pipkin FB, Warren AY, et al. Progesterone enhances the tocolytic effect of ritodrine in isolated pregnant human myometrium. Am J Obstet Gynecol. Feb. 2005;192(2):458-63. X-2, X-3, X-4. [pmid: 15695987].
Check JH, Lee G, Epstein R, et al. Increased rate of preterm deliveries in untreated women with luteal phase deficiencies. Preliminary report. Gynecol Obstet Invest. 1992;33(3):183-4. X-3, X-4. [pmid: 1612531].
Check JH, Rankin A, Teichman M. The risk of fetal anomalies as a result of progesterone therapy during pregnancy. Fertil Steril. Apr. 1986;45(4):575-7. X-3. [pmid: 3956772].
Chetkowski RJ, Kiltz RJ, Salyer WR. In premature luteinization, progesterone induces secretory transformation of the endometrium without impairment of embryo viability. Fertil Steril. Aug. 1997;68(2):292-7. X-2, X-3. [pmid: 9240259].
Christian MS, Brent RL, Calda P. Embryo-fetal toxicity signals for 17 alpha-hydroxyprogesterone caproate in high-risk pregnancies: A review of the non-clinical literature for embryo-fetal toxicity with progestins. Journal of Maternal-Fetal & Neonatal Medicine. Feb. 2007;20(2):89-112. X-1, X-2. [pmid: 17437208].
Cibils LA, Zuspan FP. Pharmacologic control of premature labor. Clin Obstet Gynecol. Dec. 1973;16(4):199-212. X-1, X-2, X-4. [pmid: 4150363].
Cicinelli E, de Ziegler D, Bulletti C, et al. Direct transport of progesterone from vagina to uterus. Obstet Gynecol. Mar. 2000;95(3):403-6. X-3. [pmid: 10711552].
Coleman VH, Power ML, Zinberg S, et al. Contemporary clinical issues in outpatient obstetrics and gynecology: findings of the Collaborative Ambulatory Research Network, 2001–2004: part I. Obstet Gynecol Surv. Nov. 2004;59(11):780-6. X-1, X-3. [pmid: 15502630].
Coleman VH, Power ML, Zinberg S, et al. Contemporary clinical issues in outpatient obstetrics and gynecology: findings of the Collaborative Ambulatory Research Network, 2001–2004: part II. Obstet Gynecol Surv. Nov. 2004;59(11):787-94. X-1, X-3. [pmid: 15502631].
Conly PW, Morrison T, Sandberg DH, et al. Concentrations of progesterone in the plasma of mothers and infants at time of birth. Pediatr Res. Jan. 1970;4(1):76-81. X-3, X-4, X-5. [pmid: 5461360].
Cooper ES, Brooks AN, Miller MR, et al. Corticotrophin-releasing factor immunostaining is present in placenta and fetal membranes from the first trimester onwards and is not affected by labour or administration of mifepristone. Clin Endocrinol (Oxf). Nov. 1994;41(5):677-83. X-3. [pmid: 7828359].
Cope E. Habitual Abortion Treated with 17 α-hydroxyprogesterone capronate. Journal of Obstetrics and Gynaecology. 1965;72(6):1035-1037. X-3.
Copper RL, Goldenberg RL, Das A, et al. The preterm prediction study: maternal stress is associated with spontaneous preterm birth at less than thirty-five weeks’ gestation. National Institute of Child Health and Human Development Maternal-Fetal Medicine Units Network. Am J Obstet Gynecol. Nov. 1996;175(5):1286-92. X-3. [pmid: 8942502].
Cousins LM, Hobel CJ, Chang RJ, et al. Serum progesterone and estradiol-17beta levels in premature and term labor. Am J Obstet Gynecol. Mar. 15. 1977;127(6):612-5. X-3. [pmid: 842587].
Csapo A, Pohanka O, Kaihola HL. Letter: Steroid profile of threatened premature labour. Lancet. Nov. 10. 1973;2(7837):1097-8. X-1. [pmid: 4127365].
Csapo AI. Model experiments and clinical trials in the control of pregnancy and parturition. Am J Obstet Gynecol. Feb. 1. 1963;85:359-79. X-1, X-2, X-3, X-4. [pmid: 14024102].
Csapo AI. Effects of progesterone, prostaglandin F2alpha and its analogue ICI 81008 on the excitability and threshold of the uterus. Am J Obstet Gynecol. Feb. 15. 1976;124(4):367-78. X-2, X-3. [pmid: 943144].
Csapo AI. The ‘see-saw’ theory of parturition. Ciba Found Symp. 1977;47:159-210. X-1, X-2, X-3, X-4. [pmid: 246391].
Csapo AI, Herczeg J. Arrest of premature labor by isoxsuprine. Am J Obstet Gynecol. Nov. 1. 1977;129(5):482-91. X-3, X-4. [pmid: 910835].
Csapo AI, Knobil E, van der Molen HJ, et al. Peripheral plasma progesterone levels during human pregnancy and labor. Am J Obstet Gynecol. Jul. 1. 1971;110(5):630-2. X-3, X-4. [pmid: 5563225].
Csapo AI, Pohanka O, Kaihola HL. Progesterone deficiency and premature labour. Br Med J. Jan. 26. 1974;1(5899):137-40. X-3, X-4. [pmid: 4812406].
Cypher R. Gestiva for preventing prematurity: a new view of an old therapy. Nurs Womens Health. Jun. 2007;11(3):322-5. X-1, X-2, X-4. [pmid: 17883780].
Czeizel A, Huiskes N. A case-control study to evaluate the risk of congenital anomalies as a result of allylestrenol therapy during pregnancy. Clin Ther. 1988;10(6):725-39. X-3. [pmid: 3219686].
Czeizel AE, Dudas I, Gidai J, et al. No effect of human chorionic gonadotropin treatment due to threatened abortion in early pregnancy for birth outcomes. Central European Journal of Medicine. 2008;3(1):71-76. X-3, X-4.
Dalton K. Prenatal progesterone and educational attainments. Br J Psychiatry. Nov. 1976;129:438-42. X-3. [pmid: 990657].
Darling MR, Hawkins DF. Sex hormones in pregnancy. Clin Obstet Gynaecol. Aug. 1981;8(2):405-19. X-1, X-2, X-3, X-4. [pmid: 7028351].
Darne J, McGarrigle HH, Lachelin GC. Increased saliva oestriol to progesterone ratio before preterm delivery: a possible predictor for preterm labor?. Br Med J (Clin Res Ed). Jan. 31. 1987;294(6567):270-2. X-3.
Davis ME, Wied GL. 17-Alpha-hydroxyprogesterone-caproate: a new substance with prolonged progestational activity; a comparison with chemically pure progesterone. J Clin Endocrinol Metab. Aug. 1955;15(8):923-30. X-2, X-3, X-4. [pmid: 13242645].
De Meeus JB, Pourrat O, Gombert J, et al. C-reactive protein levels at the onset of labour and at day 3 post-partum in normal pregnancy. Clin Exp Obstet Gynecol. 1998;25(1–2):9-11. X-3. [pmid: 9743869].
Di Renzo GC, Rosati A, Mattei A, et al. The changing role of progesterone in preterm labour. BJOG. Mar. Suppl 1. 2005;112:57-60. X-1. [pmid: 15715596].
Diaz-Zagoya JC, Arias F. Synthesis and catabolism of progesterone in placentas from normotensive and severely hypertensive patients before and after parturition. Am J Obstet Gynecol. Nov. 15. 1981;141(6):637-40. X-3. [pmid: 6947691].
Dickey RP, Thompson JP. Effect of ACTH and metyrapone on estriol, 17-hydroxycorticosteroid, 17-ketosteroid, pregnanediol and pregnanetriol excretion late in pregnancy. J Clin Endocrinol Metab. May. 1969;29(5):701-6. X-2, X-3, X-4. [pmid: 4305618].
Dodd JM, Crowther CA, Cincotta R, et al. Progesterone supplementation for preventing preterm birth: a systematic review and meta-analysis. Acta Obstet Gynecol Scand. Jun. 2005;84(6):526-33. X-1. [pmid: 15901258].
Dodd JM, Crowther CA, McPhee AJ, et al. Progesterone after previous preterm birth for prevention of neonatal respiratory distress syndrome (PROGRESS) a randomised controlled trial. BMC Pregnancy Childbirth. 2009;9:6. X-4. [pmid: 19239712].
Dodd JM, Flenady V, Cincotta R, et al. Prenatal administration of progesterone for preventing preterm birth. Cochrane Database Syst Rev. 2006;(1):CD004947. X-1. [pmid: 16437505].
Doerr HG, Sippell WG, Versmold HT, et al. Plasma mineralocorticoids, glucocorticoids, and progestins in premature infants: longitudinal study during the first week of life. Pediatr Res. May. 1988;23(5):525-9. X-2, X-3. [pmid: 3387174].
Dorfman SG, Dillaplain RP, Gambrell RD Jr. Antepartum pituitary infarction. Obstet Gynecol. Mar. 1979;53(3 Suppl):21S-24S. X-2, X-3. [pmid: 424120].
Duan L, Yan D, Zeng W, et al. Effect of progesterone treatment due to threatened abortion in early pregnancy for obstetric and perinatal outcomes. Early Hum Dev. Jan. 2010;86(1):41-3. X-3. [pmid: 20079582].
Eddama O, Petrou S, Regier D, et al. Study of progesterone for the prevention of preterm birth in twins (STOPPIT): findings from a trial-based cost-effectiveness analysis. Int J Technol Assess Health Care. Apr. 2010;26(2):141-8. X-3. [pmid: 20392316].
Edelstam G, Karlsson C, Westgren M, et al. Human chorionic gonadatropin (hCG) during third trimester pregnancy. Scand J Clin Lab Invest. 2007;67(5):519-25. X-3. [pmid: 17763188].
Elovitz MA, Mrinalini C. The use of progestational agents for preterm birth: lessons from a mouse model. Am J Obstet Gynecol. Oct. 2006;195(4):1004-10. X-2. [pmid: 17000233].
Equils O, Nambiar P, Hobel CJ, et al. A computer simulation of progesterone and Cox2 inhibitor treatment for preterm labor. PLoS One. 2010;5(1):e8502. X-3. [pmid: 20111699].
Ersch J, Beinder E, Stallmach T, et al. 17-Hydroxyprogesterone in premature infants as a marker of intrauterine stress. J Perinat Med. 2008;36(2):157-60. X-2, X-3. [pmid: 18211251].
Facchinetti F, Fazzio M, Venturini P. Polyunsaturated fatty acids and risk of preterm delivery. Eur Rev Med Pharmacol Sci. Jan-Feb. 2005;9(1):41-8. X-1, X-2, X-3, X-4. [pmid: 15850143].
Feldberg D, Goldman GA, Ashkenazi J, et al. The impact of high progesterone levels in the follicular phase of in vitro fertilization (IVF) cycles: A comparative study. Journal of In Vitro Fertilization and Embryo Transfer. 1989;6(1):11-14. X-3. [pmid: 2708871].
Ferencz C, Matanoski GM, Wilson PD, et al. Maternal hormone therapy and congenital heart disease. Teratology. Apr. 1980;21(2):225-39. X-3. [pmid: 7394725].
Ferre F, Uzan M, Janssens Y, et al. Oral administration of micronized natural progesterone in late human pregnancy. Effects on progesterone and estrogen concentrations in the plasma, placenta, and myometrium. Am J Obstet Gynecol. Jan. 1. 1984;148(1):26-34. X-3, X-4. [pmid: 6691378].
Ferre F, Uzan M, Jolivet A, et al. Influence of the oral administration of micronized progesterone on plasma and tissue levels of steroids in human pregnancy. Acta Physiol Hung. 1985;65(4):443-51. X-3, X-4. [pmid: 4013776].
Fogel M, Rubin BL, Ossowski R. Serum follicle-stimulating and luteinizing hormone and progesterone in single and multiple gestations following induction of ovulation. Am J Obstet Gynecol. Mar. 1972;112(5):629-39. X-2, X-3, X-4. [pmid: 5059593].
Fox ME, Harris RE, Brekken AL. The active-duty military pregnancy: a new high-risk category. Am J Obstet Gynecol. Nov. 15. 1977;129(6):705-7. X-3, X-4. [pmid: 920773].
Franczak J, Jagiello-Wojtowicz E, Kaminska H. The estimation of progesterone (P) in preterm delivery. Ann Univ Mariae Curie Sklodowska [Med]. 1995;50:157-60. X-3, X-4.
Fuchs AR, Fuchs F. Mechanism and prevention of preterm birth. Prog Clin Biol Res. 1985;163B:223-30. X-1, X-2, X-3, X-4. [pmid: 2858861].
Fuchs F. Prevention of prematurity. Am J Obstet Gynecol. Dec. 1. 1976;126(7):809-20. X-1, X-2, X-3, X-4. [pmid: 11689].
Fuller WE. Management of premature labor. Clin Obstet Gynecol. Jun. 1978;21(2):533-45. X-1, X-2. [pmid: 668240].
Gal I. Risks and benefits of the use of hormonal pregnancy test tablets. Nature. Nov. 24. 1972;240(5378):241-2. X-3, X-4. [pmid: 4569422].
Garfield RE. Control of myometrial function in preterm versus term labor. Clin Obstet Gynecol. Sep. 1984;27(3):572-91. X-1. [pmid: 6488606].
Garfield RE, Kannan MS, Daniel EE. Gap junction formation in myometrium: control by estrogens, progesterone, and prostaglandins. Am J Physiol. Mar. 1980;238(3):C81-9. X-2, X-3, X-4. [pmid: 7369350].
Garfield RE, Puri CP, Csapo AI. Endocrine, structural, and functional changes in the uterus during premature labor. Am J Obstet Gynecol. Jan. 1. 1982;142(1):21-7. X-2, X-3. [pmid: 7055167].
Gatelais F, Berthelot J, Beringue F, et al. Effect of single and multiple courses of prenatal corticosteroids on 17-hydroxyprogesterone levels: implication for neonatal screening of congenital adrenal hyperplasia. Pediatr Res. Nov. 2004;56(5):701-5. X-3. [pmid: 15371568].
Gay J. Theories regarding endocrine contributions to the onset of labor. JOGN Nurs. Sep-Oct. 1978;7(5):42-7. X-1, X-2. [pmid: 251750].
Genuis SJ. Fielding a current idea: exploring the public health impact of electromagnetic radiation. Public Health. Feb. 2008;122(2):113-124. X-1, X-3. [pmid: 17572456].
Gibbs CE. Diagnosis and treatment of uterine conditions that may cause permaturity. Clin Obstet Gynecol. Dec. 1973;16(4):159-70. X-1, X-2. [pmid: 4593950].
Gleicher N. Graft-versus-host disease and immunologic rejection: Implications for diagnosis and treatments of pregnancy complications. Expert Review of Obstetrics and Gynecology. Jan. 2008;3(1):37-49. X-1, X-3.
Godo B, Visser HK, Degenhart HJ. Plasma 17-OH-progesterone in fullterm and preterm infants at birth and during the early neonatal period. Horm Res. 1981;15(2):65-71. X-3, X-4. [pmid: 7327530].
Goldenberg RL. The management of preterm labor. Obstet Gynecol. Nov. 2002;100(5 Pt 1):1020-37. X-1. [pmid: 12423870].
Goldstein P, Berrier J, Rosen S, et al. A meta-analysis of randomized control trials of progestational agents in pregnancy. Br J Obstet Gynaecol. Mar. 1989;96(3):265-74. X-1. [pmid: 2653414].
Goldzieher JW. Double-Blind Trial of a Progestin in Habitual Abortion. JAMA. May. 18. 1964;188:651-4. X-3, X-4. [pmid: 14121287].
Gotkin JL, Celver J, McNutt P, et al. Progesterone reduces lipopolysaccharide induced interleukin-6 secretion in fetoplacental chorionic arteries, fractionated cord blood, and maternal mononuclear cells. Am J Obstet Gynecol. Oct. 2006;195(4):1015-9. X-2, X-3. [pmid: 17000234].
Gruneiro-Papendieck L, Prieto L, Chiesa A, et al. Neonatal screening program for congenital adrenal hyperplasia: adjustments to the recall protocol. Horm Res. 2001;55(6):271-7. X-2, X-3. [pmid: 11805430].
Grunieiro-Papendieck L, Chiesa A, Mendez V, et al. Neonatal screening for congenital adrenal hyperplasia: experience and results in Argentina. J Pediatr Endocrinol Metab. Jan. 2008;21(1):73-8. X-2, X-3. [pmid: 18404975].
Hadjigeorgiou E, Malamitsi-Puchner A, Lolis D, et al. Cardiovascular birth defects and antenatal exposure to female sex hormones. Dev Pharmacol Ther. 1982;5(1–2):61-7. X-3. [pmid: 7151638].
Hagler S, Schultz A, Hankin H, et al. Fetal Effects of Steroid Therapy During Pregnancy. Am J Dis Child. Dec. 1963;106:586-90. X-2. [pmid: 14063709].
Hajagos-Toth J, Kormanyos Z, Falkay G, et al. Potentiation of the uterus-relaxing effects of beta-adrenergic agonists with nifedipine: studies on rats and the human myometrium. Acta Obstet Gynecol Scand. Oct. 2010;89(10):1284-9. X-2, X-3. [pmid: 20846061].
Haning RV Jr, Kiggens AJ, Leiheit TL. Maternal serum progesterone, 17beta-estradiol and estriol are increased in pregnancies which follow treatment with human menopausal gonadotropins: Effects of multiple gestation and maternal endocrine status. Journal of Steroid Biochemistry. 1985;22(6):823-829. X-3. [pmid: 3927064].
Haning RV Jr, Curet LB, Poole WK, et al. Effects of fetal sex and dexamethasone on preterm maternal serum concentrations of human chorionic gonadotropin, progesterone, estrone, estradiol, and estriol. Am J Obstet Gynecol. Dec. 1989;161(6 Pt 1):1549-53. X-3. [pmid: 2690631].
Haning RV Jr, Goldsmith LT, Seifer DB, et al. Relaxin secretion in in vitro fertilization pregnancies. Am J Obstet Gynecol. Jan. 1996;174(1 Pt 1):233-40. X-3. [pmid: 8572013].
Haning RV Jr, Kiggens AJ, Leiheit TL. Maternal serum progesterone, 17 beta-estradiol and estriol are increased in pregnancies which follow treatment with human menopausal gonadotropins: effects of multiple gestation and maternal endocrine status. J Steroid Biochem. Jun. 1985;22(6):823-9. X-3. [pmid: 3927064].
Hanssens MC, Selby C, Filshie GM, et al. Changes in plasma steroid hormones during treatment of preterm labour with ritodrine-HCl. Br J Obstet Gynaecol. Sep. 1983;90(9):847-53. X-3. [pmid: 6615742].
Hanssens MC, Selby C, Symonds EM. Sex steroid hormone concentrations in preterm labour and the outcome of treatment with ritodrine. Br J Obstet Gynaecol. Jul. 1985;92(7):698-702. X-3. [pmid: 4016029].
Harger JH. Comparison of success and morbidity in cervical cerclage procedures. Obstet Gynecol. Nov. 1980;56(5):543-8. X-3. [pmid: 7001296].
Harlap S, Prywes R, Davies AM. Letter: Birth defects and oestrogens and progesterones in pregnancy. Lancet. Mar. 22. 1975;1(7908):682-3. X-1. [pmid: 47104].
Hawkins DF. Management of premature labour. Journal of Obstetrics and Gynaecology. 1989;10(SUPPL 1):S10-S12. X-1, X-2.
Hedegaard M, Henriksen TB, Sabroe S, et al. The relationship between psychological distress during pregnancy and birth weight for gestational age. Acta Obstet Gynecol Scand. Jan. 1996;75(1):32-9. X-3. [pmid: 8560994].
Heinonen OP, Slone D, Monson RR, et al. Cardiovascular birth defects and antenatal exposure to female sex hormones. N Engl J Med. Jan. 13. 1977;296(2):67-70. X-3. [pmid: 830309].
Henderson D, Wilson T. Reduced binding of progesterone receptor to its nuclear response element after human labor onset. Am J Obstet Gynecol. Sep. 2001;185(3):579-85. X-3. [pmid: 11568781].
Henderson JJ, Newnham JP, Simmer K, et al. Effects of antenatal corticosteroids on urinary markers of the initiation of lactation in pregnant women. Breastfeed Med. Dec. 2009;4(4):201-6. X-3. [pmid: 19772378].
Hendrickx AG, Korte R, Leuschner F, et al. Embryotoxicity of sex steroidal hormones in nonhuman primates: II. Hydroxyprogesterone caproate, estradiol valerate. Teratology. Feb. 1987;35(1):129-36. X-2, X-3. [pmid: 3563931].
Hercz P. Quantitative changes in steroid and peptide hormones in the maternal-fetoplacental system between the 28th-40th weeks of pregnancy. Acta Med Hung. 1985;42(1–2):29-39. X-3. [pmid: 4034335].
Hercz P, Ungar L, Siklos P. Perinatal progesterone in maternal-fetoplacental system during mature and premature deliveries. Acta Obstet Gynecol Scand. 1988;67(3):233-5. X-3. [pmid: 3176943].
Herman A, Ron-El R, Golan A, et al. Impaired corpus luteum function and other undesired results of pregnancies associated with inadvertent administration of a long-acting agonist of gonadotrophin-releasing hormone. Hum Reprod. Apr. 1992;7(4):465-8. X-2, X-3. [pmid: 1325988].
Hingre RV, Gross SJ, Hingre KS, et al. Adrenal steroidogenesis in very low birth weight preterm infants. J Clin Endocrinol Metab. Feb. 1994;78(2):266-70. X-2, X-3. [pmid: 8106610].
Hiort O, Holterhus PM, Werner R, et al. Homozygous disruption of P450 side-chain cleavage (CYP11A1) is associated with prematurity, complete 46,XY sex reversal, and severe adrenal failure. J Clin Endocrinol Metab. Jan. 2005;90(1):538-41. X-1, X-2, X-3. [pmid: 15507506].
Hirota Y, Cha J, Dey SK. Revisiting reproduction: Prematurity and the puzzle of progesterone resistance. Nat Med. May. 2010;16(5):529-31. X-1, X-2, X-3, X-4. [pmid: 20448578].
Hobel CJ. Stress and preterm birth. Clin Obstet Gynecol. Dec. 2004;47(4):856-80. discussion 881–2. X-1, X-2, X-4. [pmid: 15596939].
Hobel CJ, Dunkel-Schetter C, Roesch SC, et al. Maternal plasma corticotropin-releasing hormone associated with stress at 20 weeks’ gestation in pregnancies ending in preterm delivery. Am J Obstet Gynecol. Jan. 1999;180(1 Pt 3):S257-63. X-3. [pmid: 9914629].
Hofmann GE, Bentzien F, Bergh PA, et al. Premature luteinization in controlled ovarian hyperstimulation has no adverse effect on oocyte and embryo quality. Fertil Steril. Oct. 1993;60(4):675-9. X-3. [pmid: 8405524].
Honour J. Biochemical aspects of congenital adrenal hyperplasia. J Inherit Metab Dis. Suppl 1. 1986;9:124-34. X-3. [pmid: 3097411].
Huey QB, Rajadurai VS. Strategies for preventing chronic lung disease in premature babies. Perinatology. Mar. 2007;9(2):51-65. X-3.
Huysman MW, Hokken-Koelega AC, De Ridder MA, et al. Adrenal function in sick very preterm infants. Pediatr Res. Nov. 2000;48(5):629-33. X-3. [pmid: 11044483].
Iams JD. Supplemental progesterone to prevent preterm birth. Am J Obstet Gynecol. Feb. 2003;188(2):303. X-1, X-2, X-4. [pmid: 12592229].
Iams JD, Goldenberg RL, Mercer BM, et al. The Preterm Prediction Study: recurrence risk of spontaneous preterm birth. National Institute of Child Health and Human Development Maternal-Fetal Medicine Units Network. Am J Obstet Gynecol. May. 1998;178(5):1035-40. X-3. [pmid: 9609580].
Ibanez L, Potau N, De Zegher F. Endocrinology and metabolism after premature pubarche in girls. Acta Paediatr Suppl. Dec. 1999;88(433):73-7. X-3. [pmid: 10626549].
Imai A, Khan AA, Tamaya T. Sex steroids enhance endotoxin-stimulated phospholipase A2 activity in hum endometrial cells. Arch Gynecol Obstet. 1991;249(3):129-34. X-3. [pmid: 1772265].
Ingemarsson I. Pharmacology of tocolytic agents. Clin Obstet Gynaecol. Aug. 1984;11(2):337-51. X-3. [pmid: 6148167].
Itskovitz-Eldor J, Kol S, Mannaerts B. Use of a single bolus of GnRH agonist triptorelin to trigger ovulation after GnRH antagonist ganirelix treatment in women undergoing ovarian stimulation for assisted reproduction, with special reference to the prevention of ovarian hyperstimulation syndrome: preliminary report: short communication. Hum Reprod. Sep. 2000;15(9):1965-8. X-2, X-3. [pmid: 10966996].
Janne O, Perheentupa J, Viinikka L, et al. Plasma pregnenolone, progesterone, 17-hydroxyprogesterone, testosterone and 5alpha-dihydrotestosterone in different types of congenital adrenal hyperplasia. Clin Endocrinol (Oxf). Jan. 1975;4(1):39-48. X-2, X-3, X-4. [pmid: 1122653].
Jarczok T, Zwirner M, Schindler AE. Progesterone and 5 alpha-pregnane-3,20-dione in human amniotic fluid. Exp Clin Endocrinol. Mar. 1987;89(1):39-47. X-3. [pmid: 3595731].
Jewelewicz R, James SL, Finster M, et al. Quintuplet gestation after ovulation induction with menopausal gonadotropins and pituitary luteinizing hormone. Obstet Gynecol. Jul. 1972;40(1):1-5. X-2, X-3, X-4. [pmid: 5065192].
Jeyasuria P, Wetzel J, Bradley M, et al. Progesterone-regulated caspase 3 action in the mouse may play a role in uterine quiescence during pregnancy through fragmentation of uterine myocyte contractile proteins. Biol Reprod. May. 2009;80(5):928-34. X-2, X-3. [pmid: 19144964].
Johnson JW, Dubin NH. Prevention of preterm labor. Clin Obstet Gynecol. Mar. 1980;23(1):51-73. X-1, X-2. [pmid: 7363530].
Jouppila P. Prognosis of threatened early pregnancy. J Perinat Med. Suppl 1. 1981;9:72-4. X-3, X-4. [pmid: 6971927].
Joy S, Rhea DJ, Istwan NB, et al. The risk for preterm labor in women receiving 17 alpha-hydroxyprogesterone caproate prophylaxis for preterm birth prevention. Am J Perinatol. Apr. 2010;27(4):343-8. X-4. [pmid: 20013580].
Jung H. The role of progesterone and gestagens in the protective mechanism of pregnancy and in therapy. Bibl Gynaecol. 1966;42:69-78. X-1, X-2, X-4. [pmid: 6007136].
Kalantaridou SN, Calis KA, Mazer NA, et al. A pilot study of an investigational testosterone transdermal patch system in young women with spontaneous premature ovarian failure. J Clin Endocrinol Metab. Dec. 2005;90(12):6549-52. X-3, X-4. [pmid: 16174721].
Katz Z, Lancet M, Skornik J, et al. Teratogenicity of progestogens given during the first trimester of pregnancy. Obstet Gynecol. Jun. 1985;65(6):775-80. X-3. [pmid: 3158848].
Keirse MJ. Progestogen administration in pregnancy may prevent preterm delivery. Br J Obstet Gynaecol. Feb. 1990;97(2):149-54. X-1. [pmid: 2138496].
Khan AA, Imai A, Tamaya T. Possible mechanism for preterm labor associated with bacterial infection. II: Enhancement of endotoxin-stimulated phosphoinositide metabolism by sex steroids in human endometrial fibroblasts. Res Commun Chem Pathol Pharmacol. Jul. 1990;69(1):123-6. X-2, X-3. [pmid: 2171112].
Kilicdag EB, Haydardedeoglu B, Cok T, et al. Premature progesterone elevation impairs implantation and live birth rates in GnRH-agonist IVF/ICSI cycles. Arch Gynecol Obstet. Apr. 2010;281(4):747-52. X-3. [pmid: 19862542].
King JL, Naber JM, Hopkin RJ, et al. Antenatal corticosteroids and newborn screening for congenital adrenal hyperplasia. Arch Pediatr Adolesc Med. Sep. 2001;155(9):1038-42. X-3. [pmid: 11529806].
Klaus MH, Trause MA, Kennell JH. Does human maternal behaviour after delivery show a characteristic pattern?. Ciba Found Symp. 1975;33:69-85. X-3. [pmid: 1045987].
Kleinstein J. Efficacy and tolerability of vaginal progesterone capsules (Utrogest 200) compared with progesterone gel (Crinone 8%) for luteal phase support during assisted reproduction. Fertil Steril. Jun. 2005;83(6):1641-9. X-3. [pmid: 15950631].
Knudsen UB. Cervical ripening. A rat model for investigation of contractile and passive biomechanical properties, with focus on antigestagens, eosinophil granulocytes and mast cells. Acta Obstet Gynecol Scand. Jan. 1996;75(1):88-9. X-2, X-3, X-4. [pmid: 8561009].
Knudtzon J, Markestad T, Aakvaag A, et al. Elevated 17-hydroxyprogesterone levels in premature infants. Acta Paediatrica Scandinavica. 1991;80(1):96-97. X-3, X-4. [pmid: 2028797].
Kohrman AF, Jones LA, Bern HA. Letter: Risks and benefits of hormonal agents in pregnancy. N Engl J Med. Mar. 11. 1976;294(11):614-5. X-1. [pmid: 942759].
Kramer MS, Demissie K, Yang H, et al. The contribution of mild and moderate preterm birth to infant mortality. Fetal and Infant Health Study Group of the Canadian Perinatal Surveillance System. JAMA. Aug. 16. 2000;284(7):843-9. X-3. [pmid: 10938173].
Kumar D, Goodno JA, Barnes AC. In Vivo Effects of Intravenous Progesterone Infusion on Human Gravid Uterine Contractility. Bull Johns Hopkins Hosp. Aug. 1963;113:53-6. X-2, X-3, X-4. [pmid: 14049419].
Lachelin GC, Brant HA, Swyer GI, et al. Sextuplet pregnancy. Br Med J. Mar. 25. 1972;1(5803):787-90. X-2, X-3, X-4. [pmid: 5014254].
Lachelin GC, McGarrigle HH, Seed PT, et al. Low saliva progesterone concentrations are associated with spontaneous early preterm labour (before 34 weeks of gestation) in women at increased risk of preterm delivery. BJOG. Oct. 2009;116(11):1515-9. X-3. [pmid: 19614937].
Lanier AP, Noller KL, Decker DG, et al. Cancer and stilbestrol. A follow-up of 1,719 persons exposed to estrogens in utero and born 1943–1959. Mayo Clin Proc. Nov. 1973;48(11):793-9. X-3, X-4. [pmid: 4758151].
Lee JE, Moon Y, Lee MH, et al. Corrected 17-alpha-hydroxyprogesterone values adjusted by a scoring system for screening congenital adrenal hyperplasia in premature infants. Ann Clin Lab Sci. Summer. 2008;38(3):235-40. X-3. [pmid: 18715851].
Lee MM, Rajagopalan L, Berg GJ, et al. Serum adrenal steroid concentrations in premature infants. J Clin Endocrinol Metab. Dec. 1989;69(6):1133-6. X-3. [pmid: 2531155].
Leroy MJ, Ferre F. The cyclic AMP messenger system in the human pregnant myometrium: New perspectives for the treatment of preterm labor. IRCS Medical Science. 1986;14(10):969-972. X-1, X-2, X-3, X-4.
Leslie KK, Zuckerman DJ, Schruefer J, et al. Oestrogen modulation with parturition in the human placenta. Placenta. Jan. 1994;15(1):79-88. X-3. [pmid: 8208672].
Levine L. Habitual Abortion. A Controlled Study of Progestational Therapy. West J Surg Obstet Gynecol. Jan-Feb. 1964;72:30-6. X-3, X-4. [pmid: 14107505].
Levy EP, Cohen A, Fraser FC. Hormone treatment during pregnancy and congenital heart defects. Lancet. Mar. 17. 1973;1(7803):611. X-3, X-4. [pmid: 4120679].
Lim AC, Bloemenkamp KW, Boer K, et al. Progesterone for the prevention of preterm birth in women with multiple pregnancies: the AMPHIA trial. BMC Pregnancy Childbirth. 2007;7:7. X-1. [pmid: 17578562].
Linder N, Davidovitch N, Kogan A, et al. Longitudinal measurements of 17alpha-hydroxyprogesterone in premature infants during the first three months of life. Arch Dis Child Fetal Neonatal Ed. Nov. 1999;81(3):F175-8. X-3. [pmid: 10525018].
Liu J, Matsuo H, Laoag-Fernandez JB, et al. The effects of progesterone on apoptosis in the human trophoblast-derived HTR-8/SV neo cells. Mol Hum Reprod. Dec. 2007;13(12):869-74. X-3. [pmid: 17962376].
Lockwood CJ. Testing for risk of preterm delivery. Clin Lab Med. Jun. 2003;23(2):345-60. X1, X-3. [pmid: 12848448].
Lockwood CJ, Murk W, Kayisli UA, et al. Progestin and thrombin regulate tissue factor expression in human term decidual cells. J Clin Endocrinol Metab. Jun. 2009;94(6):2164-70. X-2, X-3. [pmid: 19276228].
Lopez Bernal A, Hansell DJ, Alexander S, et al. Steroid conversion and prostaglandin production by chorionic and decidual cells in relation to term and preterm labour. Br J Obstet Gynaecol. Nov. 1987;94(11):1052-8. X-3. [pmid: 3122817].
Luo G, Abrahams VM, Tadesse S, et al. Progesterone inhibits basal and TNF-alpha-induced apoptosis in fetal membranes: a novel mechanism to explain progesterone-mediated prevention of preterm birth. Reprod Sci. Jun. 2010;17(6):532-9. X-2, X-3. [pmid: 20360593].
Lyall F, Lye S, Teoh T, et al. Expression of Gsalpha, connexin-43, connexin-26, and EP1, 3, and 4 receptors in myometrium of prelabor singleton versus multiple gestations and the effects of mechanical stretch and steroids on Gsalpha. J Soc Gynecol Investig. Sep-Oct. 2002;9(5):299-307. X-3.
Mackenzie AP, Schatz F, Krikun G, et al. Mechanisms of abruption-induced premature rupture of the fetal membranes: Thrombin enhanced decidual matrix metalloproteinase-3 (stromelysin-1) expression. Am J Obstet Gynecol. Dec. 2004;191(6):1996-2001. X-3. [pmid: 15592282].
MacKenzie LW, Garfield RE. Hormonal control of gap junctions in the myometrium. Am J Physiol. Mar. 1985;248(3 Pt 1):C296-308. X-2, X-3. [pmid: 3976879].
Mackenzie R, Walker M, Armson A, et al. Progesterone for the prevention of preterm birth among women at increased risk: a systematic review and meta-analysis of randomized controlled trials. Am J Obstet Gynecol. May. 2006;194(5):1234-42. X-1. [pmid: 16647905].
MacRae DJ, Mohamedally SM, Willmot MP. Clinical and endocrinological aspects of dysmaturity and the use of intermittent abdominal decompression in pregnancy. J Obstet Gynaecol Br Commonw. Jul. 1971;78(7):636-41. X-3, X-4. [pmid: 5558855].
Mahajan DK, Anderson G, Poole WK, et al. Changes in the concentration of 17 alpha,20 alpha-dihydroxypregn-4-en-3-one during pregnancy, labor, and delivery and the effect of dexamethasone treatment during the third trimester of pregnancy. J Clin Endocrinol Metab. Sep. 1983;57(3):585-91. X-3. [pmid: 6874891].
Margolis KL, Bonds DE, Rodabough RJ, et al. Effect of oestrogen plus progestin on the incidence of diabetes in postmenopausal women: results from the Women’s Health Initiative Hormone Trial. Diabetologia. Jul. 2004;47(7):1175-87. X-2, X-3. [pmid: 15252707].
Martins PG, Procianoy RS. Cortisol and 17-alpha-hydroxy-progesterone levels in infants with refractory hypotension born at 30 weeks of gestation or less. Braz J Med Biol Res. Apr. 2007;40(4):577-82. X-2, X-3. [pmid: 17401502].
Mathur RS, Landgrebe S, Williamson HO. Progesterone, 17-hydroxyprogesterone, estradiol, and estriol in late pregnancy and labor. Am J Obstet Gynecol. Jan. 1. 1980;136(1):25-7. X-3. [pmid: 7352482].
Mau G. Progestins during pregnancy and hypospadias. Teratology. Dec. 1981;24(3):285-7. X-3. [pmid: 7330777].
Mavroudis K, Petsos P, Zulkifli Z, et al. Trial of 17-hydroxyprogesterone caproate (Proluton Depot) in women with long-standing infertility; failure of estrogen positive feedback the following cycle. Gynecol Endocrinol. Jun. 1987;1(2):177-93. X-3. [pmid: 3140580].
Mazor M, Hershkovitz R, Chaim W, et al. Human preterm birth is associated with systemic and local changes in progesterone/17 beta-estradiol ratios. Am J Obstet Gynecol. Jul. 1994;171(1):231-6. X-3. [pmid: 8030704].
Mazor M, Hershkowitz R, Ghezzi F, et al. Maternal plasma and amniotic fluid 17 beta-estradiol, progesterone and cortisol concentrations in women with successfully and unsuccessfully treated preterm labor. Arch Gynecol Obstet. 1996;258(2):89-96. X-3. [pmid: 8779616].
McFaul PB, Traub AI, Thompson W. Premature luteinization and ovulation induction using human menopausal gonadotrophin or pure follicle stimulating hormone in patients with polycystic ovary syndrome. Acta Europaea Fertilitatis. 1989;20(3):157-161. X-3. [pmid: 2516391].
Meloni A, Melis M, Alba E, et al. Medical therapy in the management of preterm birth. J Matern Fetal Neonatal Med. Suppl 3. 2009;22:72-6. X-4. [pmid: 19925364].
Mercer BM, Goldenberg RL, Moawad AH, et al. The preterm prediction study: effect of gestational age and cause of preterm birth on subsequent obstetric outcome. National Institute of Child Health and Human Development Maternal-Fetal Medicine Units Network. Am J Obstet Gynecol. Nov. 1999;181(5 Pt 1):1216-21. X-3. [pmid: 10561648].
Meridis E, Lavery S. Drugs in reproductive medicine. Current Obstetrics and Gynaecology. Oct. 2006;16(5):281-288. X-3.
Merlino AA, Welsh TN, Tan H, et al. Nuclear progesterone receptors in the human pregnancy myometrium: evidence that parturition involves functional progesterone withdrawal mediated by increased expression of progesterone receptor-A. J Clin Endocrinol Metab. May. 2007;92(5):1927-33. X-2, X-3. [pmid: 17341556].
Mesiano S. Myometrial progesterone responsiveness and the control of human parturition. Journal of the Society for Gynecologic Investigation. May. 2004;11(4):193-202. X-1, X-3. [pmid: 15120691].
Messinis IE, Loutradis D, Domali E, et al. Alternate day and daily administration of GnRH antagonist may prevent premature luteinization to a similar extent during FSH treatment. Hum Reprod. Nov. 2005;20(11):3192-7. X-2, X-3. [pmid: 16037104].
Michaelis J, Michaelis H, Gluck E, et al. Prospective study of suspected associations between certain drugs administered during early pregnancy and congenital malformations. Teratology. Feb. 1983;27(1):57-64. X-3, X-4. [pmid: 6845218].
Miles RA, Paulson RJ, Lobo RA, et al. Pharmacokinetics and endometrial tissue levels of progesterone after administration by intramuscular and vaginal routes: a comparative study. Fertil Steril. Sep. 1994;62(3):485-90. X-3. [pmid: 8062942].
Mitchell B, Cruickshank B, McLean D, et al. Local modulation of progesterone production in human fetal membranes. J Clin Endocrinol Metab. Dec. 1982;55(6):1237-9. X-3. [pmid: 6215422].
Mitchell BF, Fang X, Wong S. Oxytocin: A paracrine hormone in the regulation of parturition?. Reviews of Reproduction. 1998;3(2):113-122. X-1, X-3. [pmid: 9685190].
Mitchell ML, Hermos RJ. Cortisol in dried blood screening specimens from newborns with raised 17-hydroxyprogesterone and congenital adrenal hyperplasia. Clin Endocrinol (Oxf). Jun. 1998;48(6):757-60. X-2, X-3. [pmid: 9713565].
Mitreski A, Radeka G. Prostacyclin and hormone levels in patients with symptoms of miscarriage and infection. Med Pregl. Sep-Oct. 2002;55(9–10):371-9. X-3. [pmid: 12584888].
Mohan AR, Bennett PR. Drugs acting on the pregnant uterus. Current Obstetrics and Gynaecology. Jun. 2006;16(3):174-180. X-1.
Moran C, Romero MDLL, Hernandez T, et al. Ovulation induction with FSH in polycystic ovarian syndrome without clomiphene citrate response. Assisted Reproductive Technology/Andrology. 1997;9(1–2):59-63. X-3.
Mosler KH. The dynamics of uterine muscle. Bibl Gynaecol. 1968;48:1-82. X-1, X-2. [pmid: 5690123].
Murphy JF, Joyce BG, Dyas J, et al. Plasma 17-hydroxyprogesterone concentrations in ill newborn infants. Arch Dis Child. Jul. 1983;58(7):532-4. X-2, X-3. [pmid: 6870334].
Naruki M, Mizutani S, Yamada R, et al. Changes in maternal serum oxytocinase activities in preterm labour. Medical Science Research. 1995;23(12):797-802. X-2, X-4.
Nathanielsz PW, Jenkins SL, Tame JD, et al. Local paracrine effects of estradiol are central to parturition in the rhesus monkey. Nat Med. Apr. 1998;4(4):456-9. X-2, X-3. [pmid: 9546793].
Niebyl JR, Blake DA, Johnson JW, et al. The pharmacologic inhibition of premature labor. Obstet Gynecol Surv. Aug. 1978;33(8):507-15. X-1 X-2 X-3. [pmid: 28500].
Niebyl JR, Blake DA, White RD, et al. The inhibition of premature labor with indomethacin. Am J Obstet Gynecol. Apr. 15. 1980;136(8):1014-9. X-3. [pmid: 7369252].
Nomura S. Immature adrenal steroidogenesis in preterm infants. Early Hum Dev. Oct. 10. 1997;49(3):225-33. X-2, X-3. [pmid: 9378083].
Norwitz ER, Snegovskikh V, Schatz F, et al. Progestin inhibits and thrombin stimulates the plasminogen activator/inhibitor system in term decidual stromal cells: implications for parturition. Am J Obstet Gynecol. Apr. 2007;196(4):382 e1-8. X-2, X-4. [pmid: 17403427].
Novy MJ. Endocrine and pharmacological factors which influence the onset of labour in rhesus monkeys. Ciba Found Symp. 1977;47:259-95. X-2, X-3. [pmid: 205394].
O’Brien JM, Ho SJ, Istwan NB, et al. Uterine activity in women receiving 17 alpha-hydroxyprogesterone caproate for the prevention of preterm birth: an observational study. Am J Perinatol. Feb. 2010;27(2):157-62. X-4. [pmid: 19644788].
Odeh M, Kaiis M, Markowitz J, et al. Progesterone levels in preterm labor are not affected by ritodrin treatment. Gynecol Obstet Invest. 1997;43(1):34-6. X-3. [pmid: 9015696].
Odibo AO, Stamilio DM, Macones GA, et al. 17alpha-hydroxyprogesterone caproate for the prevention of preterm delivery: A cost-effectiveness analysis. Obstet Gynecol. Sep. 2006;108(3 Pt 1):492-9. X-2. [pmid: 16946206].
Ogueh O, Jones J, Mitchell H, et al. Effect of antenatal dexamethasone therapy on maternal plasma human chorionic gonadotrophin, oestradiol and progesterone. Hum Reprod. Feb. 1999;14(2):303-6. X-2, X-3. [pmid: 10099968].
Ohkubo S, Shimozawa K, Matsumoto M, et al. Analysis of blood spot 17 alpha-hydroxyprogesterone concentration in premature infants--proposal for cut-off limits in screening for congenital adrenal hyperplasia. Acta Paediatr Jpn. Apr. 1992;34(2):126-33. X-2, X-3. [pmid: 1621517].
Ohno Y, Kasugai M, Kurauchi O, et al. Effect of interleukin 2 on the production of progesterone and prostaglandin E2 in human fetal membranes and its consequences for preterm uterine contractions. Eur J Endocrinol. May. 1994;130(5):478-84. X-3. [pmid: 8180676].
Okada T, Matsuzaki N, Sawai K, et al. Chorioamnionitis reduces placental endocrine functions: the role of bacterial lipopolysaccharide and superoxide anion. J Endocrinol. Dec. 1997;155(3):401-10. X-3. [pmid: 9487985].
Olgemoller B, Roscher AA, Liebl B, et al. Screening for congenital adrenal hyperplasia: adjustment of 17-hydroxyprogesterone cut-off values to both age and birth weight markedly improves the predictive value. J Clin Endocrinol Metab. Dec. 2003;88(12):5790-4. X-2, X-3. [pmid: 14671170].
Omer H, Everly GS Jr. Psychological factors in preterm labor: critical review and theoretical synthesis. Am J Psychiatry. Dec. 1988;145(12):1507-13. X-1, X-2, X-3. [pmid: 3057922].
Oner C, Schatz F, Kizilay G, et al. Progestin-inflammatory cytokine interactions affect matrix metalloproteinase-1 and -3 expression in term decidual cells: implications for treatment of chorioamnionitis-induced preterm delivery. J Clin Endocrinol Metab. Jan. 2008;93(1):252-9. X-2, X-3, X-4. [pmid: 17940116].
Palejwala S, Stein DE, Weiss G, et al. Relaxin positively regulates matrix metalloproteinase expression in human lower uterine segment fibroblasts using a tyrosine kinase signaling pathway. Endocrinology. Aug. 2001;142(8):3405-13. X-3. [pmid: 11459784].
Pandian RU. Dydrogesterone in threatened miscarriage: a Malaysian experience. Maturitas. Dec. Suppl 1. 2009;65:S47-50. X-3. [pmid: 20005647].
Paternoster DM, De Paoli M, Plebani M, et al. Risk factors and predictors of preterm delivery. Prenatal and Neonatal Medicine. 1999;4(4):308-311. X-3.
Pau DA, Mackley A, Bartoshesky L. Newborn screening levels of 17-hydroxyprogesterone in very low birth weight infants and the relationship to chronic lung disease. J Pediatr Endocrinol Metab. Sep. 2006;19(9):1119-24. X-2, X-3. [pmid: 17128559].
Paul DA, Leef KH, Stefano JL, et al. Factors influencing levels of 17-hydroxyprogesterone in very low birth weight infants and the relationship to death and IVH. J Perinatol. Apr. 2004;24(4):252-6. X-3. [pmid: 14999215].
Pedersen AM, Fulton SK, Porter L, et al. Tumor necrosis factor-alpha affects in vitro hormone production by JEG-3 choriocarcinoma cell cultures. J Reprod Immunol. May. 1995;29(1):69-80. X-3. [pmid: 8531193].
Peltier MR, Berlin Y, Tee SC, et al. Does progesterone inhibit bacteria-stimulated interleukin-8 production by lower genital tract epithelial cells?. J Perinat Med. 2009;37(4):328-33. X-2, X-3. [pmid: 19290856].
Peltier MR, Tee SC, Smulian JC. Effect of progesterone on proinflammatory cytokine production by monocytes stimulated with pathogens associated with preterm birth. Am J Reprod Immunol. Oct. 2008;60(4):346-53. X-2, X-4. [pmid: 19046141].
Petrini JR, Callaghan WM, Klebanoff M, et al. Estimated effect of 17 alpha-hydroxyprogesterone caproate on preterm birth in the United States. Obstet Gynecol. Feb. 2005;105(2):267-72. X-2. [pmid: 15684150].
Prohaczik A, Kulcsar M, Trigg T, et al. Comparison of four treatments to suppress ovarian activity in ferrets (Mustela putorius furo). Vet Rec. Jan. 16. 2010;166(3):74-8. X-2, X-3. [pmid: 20081178].
Raghupathy R, Al Mutawa E, Makhseed M, et al. Redirection of cytokine production by lymphocytes from women with pre-term delivery by dydrogesterone. Am J Reprod Immunol. Jul. 2007;58(1):31-8. X-2, X-3. [pmid: 17565545].
Raman-Wilms L, Tseng AL, Wighardt S, et al. Fetal genital effects of first-trimester sex hormone exposure: a meta-analysis. Obstet Gynecol. Jan. 1995;85(1):141-9. X-1, X-3. [pmid: 7800312].
Rasmussen KM, Kjolhede CL. Prepregnant overweight and obesity diminish the prolactin response to suckling in the first week postpartum. Pediatrics. May. 2004;113(5):e465-71. X-3. [pmid: 15121990].
Reifenstein EC Jr. Introduction of marked as well as prolonged biologic activity by esterification; 17-alpha-hydroxyprogesterone caproate, a unique progestational compound. Fertil Steril. Jan-Feb. 1957;8(1):50-79. X-1, X-2, X-3, X-4. [pmid: 13405048].
Reijnders FJ, Thomas CM, Doesburg WH, et al. Endocrine effects of 17 alpha-hydroxyprogesterone caproate during early pregnancy: a double-blind clinical trial. Br J Obstet Gynaecol. May. 1988;95(5):462-8. X-3. [pmid: 3135831].
Riley SC, Bassett NS, Berdusco ET, et al. Changes in the abundance of mRNA for type-I 3 beta-hydroxysteroid dehydrogenase/delta 5-->delta 4 isomerase in the human placenta and fetal membranes during pregnancy and labor. Gynecol Obstet Invest. 1993;35(4):199-203. X-3. [pmid: 8330763].
Rock JA, Wentz AC, Cole KA, et al. Fetal malformations following progesterone therapy during pregnancy: a preliminary report. Fertil Steril. Jul. 1985;44(1):17-9. X-3. [pmid: 4007191].
Rode L, Langhoff-Roos J, Andersson C, et al. Systematic review of progesterone for the prevention of preterm birth in singleton pregnancies. Acta Obstet Gynecol Scand. 2009;88(11):1180-9. X-1. [pmid: 19900136].
Romero R. Prevention of spontaneous preterm birth: the role of sonographic cervical length in identifying patients who may benefit from progesterone treatment. Ultrasound Obstet Gynecol. Oct. 2007;30(5):675-86. X-1, X-2. [pmid: 17899585].
Rouse DJ. The Factor V Leiden mutation does not increase the risk of pregnancy-related venous thromboembolism. Evidence-based Obstetrics and Gynecology. Mar. 2003;5(1):56. X-3.
Ruddock NK, Shi SQ, Jain S, et al. Progesterone, but not 17-alpha-hydroxyprogesterone caproate, inhibits human myometrial contractions. Am J Obstet Gynecol. Oct. 2008;199(4):391 e1-7. X-2, X-3. [pmid: 18928984].
Ruiz RJ, Saade GR, Brown CE, et al. The effect of acculturation on progesterone/estriol ratios and preterm birth in Hispanics. Obstet Gynecol. Feb. 2008;111(2 Pt 1):309-16. X-3. [pmid: 18238967].
Sallam HN, Sallam AN, Ezzeldin FE, et al. Minimal requirements for a successful outcome in anovulatory patients treated with human menopausal gonadotropins. Int J Fertil Womens Med. Jul-Aug. 2000;45(4):285-91. X-3. [pmid: 10997485].
San Roman GA, Surrey ES, Judd HL, et al. A prospective randomized comparison of luteal phase versus concurrent follicular phase initiation of gonadotropin-releasing hormone agonist for in vitro fertilization. Fertil Steril. Oct. 1992;58(4):744-9. X-3. [pmid: 1426320].
Sanchez-Ramos L, Kaunitz AM, Delke I. Progestational agents to prevent preterm birth: a meta-analysis of randomized controlled trials. Obstet Gynecol. Feb. 2005;105(2):273-9. X-1. [pmid: 15684151].
Sarno JL, Schatz F, Lockwood CJ, et al. Thrombin and interleukin-1beta regulate HOXA10 expression in human term decidual cells: implications for preterm labor. J Clin Endocrinol Metab. Jun. 2006;91(6):2366-72. X-3. [pmid: 16551735].
Sato K, Chisaka H, Okamura K, et al. Effect of the interaction between lipoxygenase pathway and progesterone on the regulation of hydroxysteroid 11-Beta dehydrogenase 2 in cultured human term placental trophoblasts. Biol Reprod. Mar. 2008;78(3):514-20. X-3. [pmid: 18032417].
Schardein JL. Congenital abnormalities and hormones during pregnancy: a clinical review. Teratology. Dec. 1980;22(3):251-70. X-1. [pmid: 7015547].
Schreyer P, Zer Y, Ariely S, et al. Plasma steroids and human placental lactogen level changes in late pregnancy in association with intravenous ritodrine administration. Gynecol Obstet Invest. 1981;12(2):99-106. X-2, X-3, X-4. [pmid: 7262636].
Schwartz N, Xue X, Elovitz MA, et al. Progesterone suppresses the fetal inflammatory response ex vivo. Am J Obstet Gynecol. Aug. 2009;201(2):211 e1-9. X-2, X-3. [pmid: 19646573].
Schwarz BE. Premature labor. Birth Defects Orig Artic Ser. 1981;17(1):85-94. X-1, X-2, X-3. [pmid: 6793110].
Scialli AR. Developmental effects of progesterone and its derivatives. Reprod Toxicol. 1988;2(1):3-11. X-1, X-2, X-4. [pmid: 2980398].
Scott EM, Thomas A, McGarrigle HHG, et al. A comparison of serial ultrasound measurements of fetal adrenal glands with maternal plasma and saliva oestriol and progesterone levels in normal pregnancy. Journal of Obstetrics and Gynaecology. 1991;11(6):381-385. X-3.
Seegmiller RE, Nelson GW, Johnson CK. Evaluation of the teratogenic potential of delalutin (17 alpha-hydroxyprogesterone caproate) in mice. Teratology. Oct. 1983;28(2):201-8. X-2, X-3. [pmid: 6648824].
Sexton DJ, O’Reilly MW, Friel AM, et al. Functional effects of 17alpha-hydroxyprogesterone caproate (17P) on human myometrial contractility in vitro. Reprod Biol Endocrinol. Dec. 7. 2004;2:80. X-3. [pmid: 15585068].
Sfakianaki AK, Norwitz ER. Mechanisms of progesterone action in inhibiting prematurity. J Matern Fetal Neonatal Med. Dec. 2006;19(12):763-72. X-1, X-3. [pmid: 17190686].
Shahin AY, Hassanin IM, Ismail AM, et al. Effect of oral N-acetyl cysteine on recurrent preterm labor following treatment for bacterial vaginosis. Int J Gynaecol Obstet. Jan. 2009;104(1):44-8. X-4. [pmid: 18851855].
Shalev J, Frankel Y, Eshkol A, et al. Breast engorgement and galactorrhea after preventing premature contractions with ritodrine. Gynecol Obstet Invest. 1984;17(4):190-3. X-2, X-3. [pmid: 6724348].
Sharma S, Ellis EC, Dorko K, et al. Metabolism of 17alpha-hydroxyprogesterone caproate, an agent for preventing preterm birth, by fetal hepatocytes. Drug Metab Dispos. May. 2010;38(5):723-7. X-3. [pmid: 20097724].
Sharma S, Ou J, Strom S, et al. Identification of enzymes involved in the metabolism of 17alpha-hydroxyprogesterone caproate: an effective agent for prevention of preterm birth. Drug Metab Dispos. Sep. 2008;36(9):1896-902. X-3. [pmid: 18573861].
Shearman RP, Garrett WJ. Double-blind study of effect of 17-hydroxyprogesterone caproate on abortion rate. Br Med J. Feb. 2. 1963;1(5326):292-5. X-3, X-4. [pmid: 13977012].
Sherman AI. Hormonal therapy for control of the incompetent os of pregnancy. Obstet Gynecol. Aug. 1966;28(2):198-205. X-4. [pmid: 5944836].
Shields AD, Wright J, Paonessa DJ, et al. Progesterone modulation of inflammatory cytokine production in a fetoplacental artery explant model. Am J Obstet Gynecol. Sep. 2005;193(3 Pt 2):1144-8. X-2, X-3. [pmid: 16157127].
Shimozawa K, Matsumoto M, Okada K, et al. Analysis of blood spot 17 alpha-hydroxyprogesterone concentration in neonates. Horm Res. 1988;30(6):246-51. X-3. [pmid: 3266938].
Shumin X, Johannisson E, Landgren BM, et al. Pituitary, ovarian and endometrial effects of progesterone released prematurely during the proliferative phase. Contraception. Feb. 1983;27(2):177-93. X-2, X-3. [pmid: 6851555].
Sibai B, Meis PJ, Klebanoff M, et al. Plasma CRH measurement at 16 to 20 weeks’ gestation does not predict preterm delivery in women at high-risk for preterm delivery. Am J Obstet Gynecol. Sep. 2005;193(3 Pt 2):1181-6. X-3, X-4. [pmid: 16157134].
Siklosi G. Luteal insufficiency as the primary cause of habitual abortion--its successful treatment. Acta Biomed Ateneo Parmense. 1992;63(1–2):101-11. X-3. [pmid: 1340655].
Siklosi G, Acs N, Demendi C, et al. Luteal function as the main determinant of pregnancy outcome: successful prevention of spontaneous abortion, prematurity and IUGR. Early Pregnancy. Jan. 2001;5(1):22-3. X-3, X-4. [pmid: 11743633].
Smit DA, Essed GG, de Haan J. Predictive value of uterine contractility and the serum levels of progesterone and oestrogens with regard to preterm labour. Gynecol Obstet Invest. 1984;18(5):252-63. X-3. [pmid: 6526341].
Smith R, Smith JI, Shen X, et al. Patterns of plasma corticotropin-releasing hormone, progesterone, estradiol, and estriol change and the onset of human labor. J Clin Endocrinol Metab. Jun. 2009;94(6):2066-74. X-3. [pmid: 19258402].
Snegovskikh VV, Schatz F, Arcuri F, et al. Intra-amniotic infection upregulates decidual cell vascular endothelial growth factor (VEGF) and neuropilin-1 and -2 expression: implications for infection-related preterm birth. Reprod Sci. Aug. 2009;16(8):767-80. X-2, X-3. [pmid: 19474288].
So KW, Ng PC. Treatment and prevention of neonatal osteopenia. Current Paediatrics. Apr. 2005;15(2):106-113. X-3.
Soiva K, Castren O. Conservative treatment of threatened premature labour. Acta Obstet Gynecol Scand. 1965;44(2):281-8. X-3, X-4. [pmid: 5834179].
Stamatelou F, Deligeoroglou E, Farmakides G, et al. Abnormal progesterone and corticotropin releasing hormone levels are associated with preterm labour. Ann Acad Med Singapore. Nov. 2009;38(11):1011-6. X-3. [pmid: 19956826].
Strauss A, Brakin M, Norris K, et al. Adrenal responsiveness in very-low-birth-weight infants treated with dexamethasone. Dev Pharmacol Ther. 1992;19(2–3):147-54. X-2, X-3. [pmid: 1340435].
Sureau C, Breart G. The prevention of premature birth. Annales Nestle. 1989;47(2):89-96. X-1, X-2, X-4.
Sweet RA, Schrott HG, Kurland R, et al. Study of the incidence of hypospadias in Rochester, Minnesota, 1940–1970 and a case-control comparison of possible etiologic factors. Mayo Clin Proc. Jan. 1974;49(1):52-8. X-3, X-4. [pmid: 4855617].
Swyer GI, Daley D. Progesterone implantation in habitual abortion. Br Med J. May. 16. 1953;1(4819):1073-7. X-3, X-4. [pmid: 13042138].
Szekeres J, Csernus V, Hadnagy J, et al. Cytotoxic activity and progesterone binding capacity of maternal lymphocytes are not influenced by gestational age and by the number of previous pregnancies. Acta Med Acad Sci Hung. 1982;39(3–4):137-43. X-3. [pmid: 7185239].
Szekeres-Bartho J, Csernus V, Hadnagy J, et al. Immunosuppressive effect of serum progesterone during pregnancy depends on the progesterone binding capacity of the lymphocytes. J Reprod Immunol. Mar. 1983;5(2):81-8. X-3. [pmid: 6132996].
Szekeres-Bartho J, Csernus V, Hadnagy J, et al. Progesterone-prostaglandin balance influences lymphocyte function in relation to pregnancy. Am J Reprod Immunol. Oct-Nov. 1983;4(3):139-41. X-3. [pmid: 6581738].
Szekeres-Bartho J, Faust Z, Varga P. The expression of a progesterone-induced immunomodulatory protein in pregnancy lymphocytes. Am J Reprod Immunol. Dec. 1995;34(6):342-8. X-3. [pmid: 8607938].
Szekeres-Bartho J, Hadnagy J, Pacsa AS. The suppressive effect of progesterone on lymphocyte cytotoxicity: unique progesterone sensitivity of pregnancy lymphocytes. J Reprod Immunol. Feb. 1985;7(2):121-8. X-4. [pmid: 3981485].
Szekeres-Bartho J, Kilar F, Falkay G, et al. The mechanism of the inhibitory effect of progesterone on lymphocyte cytotoxicity: I. Progesterone-treated lymphocytes release a substance inhibiting cytotoxicity and prostaglandin synthesis. Am J Reprod Immunol Microbiol. Sep. 1985;9(1):15-8. X-3. [pmid: 3863495].
Szekeres-Bartho J, Varga P, Pacsa AS. Immunologic factors contributing to the initiation of labor--lymphocyte reactivity in term labor and threatened preterm delivery. Am J Obstet Gynecol. Jul. 1986;155(1):108-12. X-3. [pmid: 3460338].
Szekeres-Bartho J, Varga P, Pejtsik B. ELISA test for the detection of an immunological blocking factor in human pregnancy serum. J Reprod Immunol. Sep. 1989;16(1):19-29. X-3. [pmid: 2600930].
Tamby Raja RL, Anderson AB, Turnbull AC. Endocrine changes in premature labour. Br Med J. Oct. 12. 1974;4(5936):67-71. X-3, X-4. [pmid: 4413231].
TambyRaja RL, Salmon JA. Endocrinology of normal pregnancy and premature labour. N Z Med J. Jul. 27. 1977;86(592):89-92. X-3. [pmid: 271880].
Tapanainen J, Huhtaniemi I, Koivisto M, et al. Hormonal changes during the perinatal period: FSH, prolactin and some steroid hormones in the cord blood and peripheral serum of preterm and fullterm female infants. J Steroid Biochem. May. 1984;20(5):1153-6. X-3. [pmid: 6427529].
Tempfer CB, Kurz C, Bentz EK, et al. A combination treatment of prednisone, aspirin, folate, and progesterone in women with idiopathic recurrent miscarriage: a matched-pair study. Fertil Steril. Jul. 2006;86(1):145-8. X-3. [pmid: 16716321].
Thomas S, Murphy JF, Dyas J, et al. Response to ACTH in the newborn. Arch Dis Child. Jan. 1986;61(1):57-60. X-3, X-4. [pmid: 3006603].
Thome UH, Bischoff A, Maier L, et al. Amiloride-sensitive nasal potential difference is not changed by estradiol and progesterone replacement but relates to BPD or death in a randomized trial on preterm infants. Pediatr Res. Nov. 2006;60(5):619-23. X-3. [pmid: 16988198].
Thornton JG. Progesterone and preterm labor--still no definite answers. N Engl J Med. Aug. 2. 2007;357(5):499-501. X-1, X-2, X-4. [pmid: 17671259].
Torok I, Pohanka O, Dvoracsek E, et al. Beta-adrenergic sensitivity--imminent premature delivery. Acta Physiol Hung. 1985;65(3):347-54. X-3. [pmid: 2861711].
Torresani T, Gruters A, Scherz R, et al. Improving the efficacy of newborn screening for congenital adrenal hyperplasia by adjusting the cut-off level of 17alpha-hydroxyprogesterone to gestational age. Screening. 1994;3(2):77-84. X-3.
Toth B, Avar Z, Balint T. The effectivity of Bricanyl (terbutaline) treatment in the prevention and management of threatening abortion and premature delivery, respectively, within the frames of outpatients’ services. Therapia Hungarica. 1982;30(2):88-92. X-4. [pmid: 6926911].
Toth P. Clinical data supporting the importance of vascular LH/hCG receptors of uterine blood vessels. Semin Reprod Med. 2001;19(1):55-61. X-3, X-4. [pmid: 11394204].
Trotter A, Maier L, Grill HJ, et al. Effects of postnatal estradiol and progesterone replacement in extremely preterm infants. J Clin Endocrinol Metab. Dec. 1999;84(12):4531-5. X-3. [pmid: 10599713].
Trotter A, Maier L, Grill HJ, et al. 17Beta-estradiol and progesterone supplementation in extremely low-birth-weight infants. Pediatr Res. Apr. 1999;45(4 Pt 1):489-93. X-3. [pmid: 10203139].
Trotter A, Maier L, Kohn T, et al. Growth of the uterus and mammary glands and vaginal cytologic features in extremely premature infants with postnatal replacement of estradiol and progesterone. Am J Obstet Gynecol. Feb. 2002;186(2):184-8. X-3. [pmid: 11854632].
Trotter A, Maier L, Kron M, et al. Effect of oestradiol and progesterone replacement on bronchopulmonary dysplasia in extremely preterm infants. Arch Dis Child Fetal Neonatal Ed. Mar. 2007;92(2):F94-8. X-3. [pmid: 16905572].
Trotter A, Maier L, Pohlandt F. Calcium and phosphorus balance of extremely preterm infants with estradiol and progesterone replacement. Am J Perinatol. Jan. 2002;19(1):23-9. X-3. [pmid: 11857093].
Tsapoulis AD, Zourlas PA, Comninos AC. Observations on 320 infertile patients treated with human gonadotropins (human menopausal gonadotropin/human chorionic gonadotropin). Fertil Steril. May. 1978;29(5):492-5. X-3. [pmid: 668927].
Turnbull AC, Patten PT, Flint AP, et al. Significant fall in progesterone and rise in oestradiol levels in human peripheral plasma before onset of labour. Lancet. Jan. 26. 1974;1(7848):101-3. X-3, X-4. [pmid: 4130306].
Tyson EK, Smith R, Read M. Evidence that corticotropin-releasing hormone modulates myometrial contractility during human pregnancy. Endocrinology. Dec. 2009;150(12):5617-25. X-3. [pmid: 19846610].
Unanue N, Bazaes R, Iniguez G, et al. Adrenarche in Prader-Willi syndrome appears not related to insulin sensitivity and serum adiponectin. Horm Res. 2007;67(3):152-8. X-3. [pmid: 17085944].
van der Ploeg KR, Wolthers BG, Nagel GT, et al. The diagnosis of 21-hydroxylase deficiency in a prematurely born infant on the basis of the urinary steroid excretion pattern. Clin Chim Acta. Apr. 23. 1982;120(3):341-53. X-2, X-3. [pmid: 6978779].
Varma TR, Morsman J. Evaluation of the use of Proluton-Depot (hydroxyprogesterone hexanoate) in early pregnancy. Int J Gynaecol Obstet. Feb. 1982;20(1):13-7. X-3, X-4. [pmid: 6126401].
Vassilakos P, Wyss R, Stastny J. Decidual changes during hypertonic saline-induced abortion. Am J Obstet Gynecol. Aug. 1. 1974;119(7):889-94. X-2, X-3, X-4. [pmid: 4841579].
Vidaeff AC, Ramin SM, Gilstrap LC 3rd, et al. Impact of progesterone on cytokine-stimulated nuclear factor-kappaB signaling in HeLa cells. J Matern Fetal Neonatal Med. Jan. 2007;20(1):23-8. X-3. [pmid: 17437195].
Walker J. Prognostic value of antenatal screening. Am J Obstet Gynecol. Jan. 1. 1976;124(1):30-8. X-3, X-4. [pmid: 54002].
Walker J, Hughes IA, Wood PJ. Bloodspot testosterone assay suitable for study of neonates and monitoring of children with congenital adrenal hyperplasia. Ann Clin Biochem. Jul. 1999;36(Pt 4):477-82. X-3. [pmid: 10456210].
Wallace AM, Beesley J, Thomson M, et al. Adrenal status during the first month of life in mature and premature human infants. J Endocrinol. Mar. 1987;112(3):473-80. X-3. [pmid: 3559456].
Wallace WH, Shalet SM, Tetlow LJ, et al. Ovarian function following the treatment of childhood acute lymphoblastic leukaemia. Med Pediatr Oncol. 1993;21(5):333-9. X-2. [pmid: 8492747].
Watterberg KL, Gerdes JS, Cook KL. Impaired glucocorticoid synthesis in premature infants developing chronic lung disease. Pediatr Res. Aug. 2001;50(2):190-5. X-3. [pmid: 11477202].
Weinberg MA, Maloney WJ. Periodontal changes in females. U.S. 2007 19. Pharmacist. 32(9):54-56. X-3.
Weller A, Rozin A, Goldstein A, et al. Longitudinal assessment of pituitary-thyroid axis and adrenal function in preterm infants raised by ‘kangaroo mother care’. Horm Res. 2002;57(1–2):22-6. X-3. [pmid: 12006715].
Wilkins L. Masculinization of female fetus due to use of orally given progestins. J Am Med Assoc. Mar. 5. 1960;172:1028-32. X-2, X-3. [pmid: 13844748].
Wilkins L, Jones HW Jr, Holman GH, et al. Masculinization of the female fetus associated with administration of oral and intramuscular progestins during gestation: non-adrenal female pseudohermaphrodism. J Clin Endocrinol Metab. Jun. 1958;18(6):559-85. X-3. [pmid: 13539170].
Wiseman RA, Dodds-Smith IC. Cardiovascular birth defects and antenatal exposure to female sex hormones: a reevaluation of some base data. Teratology. Dec. 1984;30(3):359-70. X-2, X-3. [pmid: 6240131].
Wolfrum R, Bordasch C, Holweg J, et al. Prognostic value of combined assay of total estrogen and pregnanediol in 24 hour urine. Experience with 500 pregnancies in an endocrine surveillance program during the second trimester. J Perinat Med. 1977;5(3):133-44. X-3, X-4. [pmid: 915684].
Wu WX, Ma XH, Zhang Q, et al. Characterization of two labor-induced genes, DSCR1 and TCTE1L, in the pregnant ovine myometrium. J Endocrinol. Jul. 2003;178(1):117-26. X-2. [pmid: 12844343].
Yalom ID, Green R, Fisk N. Prenatal exposure to female hormones. Effect on psychosexual development in boys. Arch Gen Psychiatry. Apr. 1973;28(4):554-61. X-3, X-4. [pmid: 4734959].
Yan R, Fokina V, Hankins GD, et al. The effect of esterases on 17alpha-hydroxyprogesterone caproate. Am J Obstet Gynecol. Feb. 2008;198(2):229 e1-5. X-3. [pmid: 17936237].
Yan R, Nanovskaya TN, Zharikova OL, et al. Metabolism of 17alpha-hydroxyprogesterone caproate by hepatic and placental microsomes of human and baboons. Biochem Pharmacol. May. 1. 2008;75(9):1848-57. X-3. [pmid: 18329004].
Ylikorkala O, Kauppila A, Tuimala R, et al. Effects of intravenous isoxsuprine and ritodrine, with and without concomitant dexamethasone, on fetoplacental and pituitary hormones and cyclic adenosine monophosphate during late pregnancy. Am J Obstet Gynecol. Feb. 1. 1978;130(3):302-6. X-3. [pmid: 203192].
Yokoyama M, Hinode D, Masuda K, et al. Effect of female sex hormones on Campylobacter rectus and human gingival fibroblasts. Oral Microbiol Immunol. Aug. 2005;20(4):239-43. X-3. [pmid: 15943769].
Youssef RE, Ledingham MA, Bollapragada SS, et al. The role of toll-like receptors (TLR-2 and -4) and triggering receptor expressed on myeloid cells 1 (TREM-1) in human term and preterm labor. Reprod Sci. Sep. 2009;16(9):843-56. X-3. [pmid: 19564644].
Zaremba W, Grunert E, Aurich JE. Prophylaxis of respiratory distress syndrome in premature calves by administration of dexamethasone or a prostaglandin F2 alpha analogue to their dams before parturition. Am J Vet Res. Apr. 1997;58(4):404-7. X-2, X-3. [pmid: 9099388].
Zicari A, Ticconi C, Realacci M, et al. Hormonal regulation of cytokine release by human fetal membranes at term gestation: effects of oxytocin, hydrocortisone and progesterone on tumour necrosis factor-alpha and transforming growth factor-beta 1 output. J Reprod Immunol. Jul-Aug. 2002;56(1–2):123-36. X-3. [pmid: 12106888].
Zuspan FP. Premature labor: its management and therapy. J Reprod Med. Sep. 1972;9(3):93-118. X-1, X-3, X-4. [pmid: 4403894].