# Exact Search Strings and Results

Table A-1 PubMed search strategies and results

Search terms | | Preliminary search results
#1 | obstetric labor, premature[mh] OR premature birth[mh] OR ((premature[tw] OR preterm[tw] OR pre-term[tw]) AND (labor[tw] OR labour[tw] OR birth[tw] OR births[tw] OR delivery[tiab] OR deliveries[tw])) | 48,611
#2 | “17-alpha-Hydroxyprogesterone”[mh] OR “17-OH progesterone”[tw] OR hydroxyprogesterone[tw] OR “17alpha-hydroxyprogesterone”[tw] OR 17-alpha-hydroxy-progesterone caproate [nm] OR 17-hydroxyprogesterone heptanoate [nm] OR progesterone[mh] OR progestins[pa] OR hydroxy-progesterone[tiab] OR hydroxyprogesterones[nm] OR progestogen[tiab] OR progestogens[tiab] | 70,448
#3 | #1 AND #2 AND eng[la] AND humans[mh] | 438
#4 | #3 AND editorial[pt] | 10
#5 | #3 AND letter[pt] | 14
#6 | #3 AND comment[pt] | 21
#7 | #3 AND case reports[pt] | 17
#8 | #3 AND review[pt] | 101
#9 | #3 AND practice guideline[pt] | 1
#10 | #3 AND news[pt] | 3
#11 | #3 NOT (#4 OR #5 OR #6 OR #7 OR #8 OR #9) | 294^*^

* Numbers do not tally as some items were indexed with multiple publication types

Table A-2 EMBASE Drugs and Pharmacology search terms and results

Search terms | | Search results
#1 | exp “immature and premature labor”/or ((premature or prematurity or pre-term or preterm) and (birth or births or delivery or deliveries or labor or labour)).af. | 27,151
#2 | exp gestagen/or (progesterone or hydroxyprogesterone or hydroxy-progesterone or progestogen or progestogens or progestins or progestin).af. | 95,571
#3 | #1 and #2, limited to human and English language | 820
#4 | #3 and review.pt | 281
#5 | #3 and conference paper.pt | 48
#6 | #3 and editorial.pt | 30
#6 | #3 and letter.pt | 27
#7 | #3 and note.pt | 19
#8 | #3 and short survey.pt | 14
#9 | #3 and case report/ | 48
#10 | #3 and practice guideline/ | 15
#11 | #3 and “systematic review”/ | 44
#12 | #3 and meta analysis/ | 44
#13 | #4 or #5 or #6 or #7 or #8 or #9 or #10 or #11 or #12 | 422
#14 | #3 not #13 | 351^*^

Overlap with PubMed: 321 citations

* Numbers do not tally as some items were indexed with multiple publication types