# Acronyms/Abbreviations

17P, 17OHP: 17 alpha-hydroxyprogesterone caproate
ARR: adjusted relative risk
ART: assisted reproductive techniques
BCI: Bayesian credible interval
b.i.d: two times a day
BMI: body mass index <kg/m^2^>
CI: confidence interval
CT: clinical trial
DES: diethylstilbestrol
DM: Diabetes Mellitus
gm: grams
GA: gestational age <weeks>
HIV: Human Immunodeficiency Virus
hr(s): hour(s)
IM: intramuscular (injection)
IUFD: intrauterine fetal death
IVH: intraventricular hemorrhage
LBW: low birth weight
mg(s): milligram(s)
NA: not applicable
NEC: necrotizing enterocolitis
NICHD: National Institute of Child Health and Human Development
NICU: neonatal intensive care unit
NNT: Number needed to treat
NR: not reported
NS: not significant
OB: obstetrical
OR: odds ratio
P: progesterone
PPROM: preterm premature rupture of membranes
PTB: preterm birth
PTD: preterm delivery
PTL: preterm labor
q: every
qd: every day
RCT: randomized control trial
RDS: respiratory distress syndrome
ROP: retinopathy
RR: relative risk
SD: standard deviation
U.S.: United States of America
Vent: mechanical ventilator
wk(s): week(s)