# Results

## Literature Search

The literature search yielded 3036 citations (Figure 2). Of these, 2711 were excluded at the abstract level. The remaining 325 articles were retrieved for full-text review, upon which 310 were excluded. Most of the exclusions were studies that did not meet all of the predefined PICO criteria and/or did not provide data comparing the performance of the SFLC assay with the predefined traditional tests (serum or urine tests [SPEP, UPEP, SIFE, or UIFE], bone marrow evaluation, or skeletal survey). (See Appendix B for the list of rejected articles and the rationale for their rejection.) A total of 15 studies that were both comparative and met all the CER eligibility criteria were included.

Figure 2 Summary of search and selection of articles

FLC=free light chain; KQ=Key Question; PCD=plasma cell dyscrasia; PICO=population, intervention (diagnostic test/disease monitoring), comparator, and outcome; SFLC=serum free light chain

Figure 2 is a flow chart that summarizes the search and selection of articles: There were 3036 citations identified by searching MEDLINE, the Cochrane Central Register of Controlled Trials, and the Cochrane Database of Systematic Reviews, with 2711 excluded at the abstract level. The remaining 325 articles were retrieved for full-text review, upon which 310 were excluded. Most of the exclusions were because studies did not meet all of the predefined PICO criteria and/or did not provide data comparing the performance of the SFLC assay with the predefined traditional tests. A total of 15 studies that were both comparative and met all the CER eligibility criteria were included.

All included studies either used the Freelite assay for measuring SFLCs or referred to measurement of SFLCs or to a nephelometric technique for their measurement. We targeted any data describing, or permitting the inference of, a comparison between any single or group of traditional tests (SPEP, UPEP, SIFE, or UIFE) used to detect PCDs (particularly MGUS, MM [including LCMM and NSMM], or AL amyloidosis) and the same single test or group of tests with an SFLC assay added. Studies of diagnosis, progression, and treatment of PCDs were all of interest.

## Study Quality Grade and Overall Strength of Evidence

Table 1 summarizes the relevance and quality of the 15 studies reviewed in detail. The studies are organized by which KQ they addressed and the quality grade they were assigned. The criteria met by each study and its quality grade are provided in Appendix C.

Table 1 Distribution and quality of the 15 studies addressing a KQ

| KQ1 | KQ2 | KQ3 | KQ4 | KQ5 | TOTAL
Quality A | 0 | 0 | 0 | 0 | 0 | 0
Quality B | 3 | 0 | 0 | 3 | 0 | 6
Quality C | 0 | 0 | 0 | 8 | 1 | 9
Total studies | 3 | 0 | 0 | 11 | 1 | 15
Overall strength of evidence | Insufficient | Insufficient | Insufficient | Insufficient | Insufficient

KQ=Key Question.

## KQ1 Does adding the SFLC assay and the kappa/lambda ratio to traditional testing (serum/urine electrophoresis or IFE), compared with traditional testing alone, improve the diagnostic accuracy for PCDs (MGUS, MM, NSMM, or AL amyloidosis) in undiagnosed patients suspected of having a PCD?

### Results

Three studies31-33 evaluated the addition of SFLC testing to traditional testing for the diagnosis of PCDs in undiagnosed patients suspected of having a PCD. The study characteristics and findings are listed in Tables 2, 3, and 4.

Table 2 Characteristics of studies addressing KQ1

Author Year [PMID] | Index Test/Comparator Test | Sample Size | Funding | Enrollment Period | Prospective Study? | Diagnosis Documented in Medical Records | Quality Grade and Issues
Abadie 2006^31^ [16682511] | SFLC+SPEP | 312 | Kit/reagents provided by industry | 2004–2005 | No | Yes | B (no CI provided, consecutive sampling, no major biases)
Abadie 2006^31^ [16682511] | SPEP | 312 | Kit/reagents provided by industry | 2004–2005 | No | Yes | B (no CI provided, consecutive sampling, no major biases)
Piehler 2008^32^ [18801937] | SFLC+SPEP | 489 | nd | 2005–2006 | No | Yes | B (no CI provided, consecutive recruitment, no major biases)
Piehler 2008^32^ [18801937] | SPEP | 489 | nd | 2005–2006 | No | Yes | B (no CI provided, consecutive recruitment, no major biases)
Vermeersch 2008^33^ [18729849] | SFLC+SIFE, SFLC+SIFE+SPEP | 833 | None | 2004–2006 | No | Yes | B (no CI provided, well-described sample, no major biases)
Vermeersch 2008^33^ [18729849] | SIFE, SIFE+SPEP | 833 | None | 2004–2006 | No | Yes | B (no CI provided, well-described sample, no major biases)

CI=confidence interval IFE=immunofixation electrophoresis, KQ=Key Question, nd=no data, SFLC=serum free light chain [note this can refer to the light chain itself or the assay], SIFE=serum immunofixation electrophoresis; SPEP=serum protein electrophoresis, UIFE=urine immunofixation electrophoresis, UPEP=urine protein electrophoresis.

Table 3 Characteristics of patients in studies addressing KQ1

Author Year [PMID] | Sample Size | Enrollment Method | Diagnosed Before Study? | PCD Prevalence | Age (yr) | Percent Male | Treated?
Abadie 2006^31^ [16682511] | 312 | Consecutive | No | Malignant PCD, 15% | 67 (mean) | 97 | nd
Piehler 2008^32^ [18801937] | 489 | Selection of those with SPEP testing results | No | Any PCD, 27% LCMM, 2.1% MM, 6.6% AL amyloidosis, 0.6% MGUS, 13.6% | nd | nd | nd
Vermeersch 2008^33^ [18729849] | 833 | Consecutive | No | Malignant PCD, 3%; MGUS, 19% | nd | nd | NA

AL amyloidosis=systemic amyloidosis in which amyloid [A] proteins derived from immunoglobulin light chains [L] are deposited in tissue, KQ=Key Question, LCMM=light chain myeloma, MGUS=monoclonal gammopathy of undetermined significance, MM=multiple myeloma, NA=not applicable, nd=no data, PCD=plasma cell dyscrasia.

Table 4 Results of studies addressing KQ1

Author Year [PMID] | Sample Size | Diagnosis | Index Test | Sensitivity (95% CI) | Specificity (95% CI) | Other Results
Abadie 2006^31^ [16682511] | 312 | PCD | SFLC | 0.88 (0.75, 0.97) | 0.98 (0.96, 0.99) | Considered MGUS as false positive
Abadie 2006^31^ [16682511] | 312 | PCD | SPEP | 0.64 (0.49, 0.77) | 0.81 (0.76, 0.86)
Abadie 2006^31^ [16682511] | 312 | PCD | SFLC+SPEP | 1.00 (nd) | 0.99 (nd)
Piehler 2008^32^ [18801937] | 332 | PCD | SFLC | 0.66 (nd) | 0.78 (nd) | Specificity was affected by SFLC assay positivity in patients with other hematological diagnosis or decreased kidney function
Piehler 2008^32^ [18801937] | 332 | PCD | SPEP | 0.87 (nd) | 0.98 (nd)
Piehler 2008^32^ [18801937] | 332 | PCD | SFLC+SPEP | 0.96 (nd) | 0.78 (nd)
Vermeersch 2008^33^ [18729849] | 833 | Monoclonal gammopathy^*^ | SFLC | 0.37 (nd) | 0.97 (nd) | Missed 3 MM, 1 plasmacytoma, 112 MGUS cases
Vermeersch 2008^33^ [18729849] | 833 | Monoclonal gammopathy^*^ | SIFE | 0.92 (nd) | 1.00 (nd) | Missed 2 MGUS cases
Vermeersch 2008^33^ [18729849] | 833 | Monoclonal gammopathy^*^ | SFLC+SIFE | 0.94 (nd) | 0.97 (nd) | Missed 1 MGUS cases
Vermeersch 2008^33^ [18729849] | 833 | Monoclonal gammopathy^*^ | SPEP (+SIFE for confirmation) | 0.79 (nd) | 1.00 (nd) | Missed 1 MM, 1 AL amyloidosis, 1 plasmacytoma, 26 MGUS cases
Vermeersch 2008^33^ [18729849] | 833 | Monoclonal gammopathy^*^ | SFLC+ SPEP (+SIFE for confirmation) | 0.82 (nd) | 0.97 (nd) | Missed 1 plasmacytoma, 23 MGUS cases
Vermeersch 2008^33^ [18729849] | 833 | Monoclonal gammopathy^*^ | UIFE+ SPEP (+SIFE for confirmation) | 0.82 (nd) | 1.00 (nd) | Missed 24 MGUS cases
Vermeersch 2008^33^ [18729849] | 833 | Monoclonal gammopathy^*^ | SIFE+UIFE | 0.92 (nd) | 1.00 (nd) | Missed 2 MGUS cases

AL amyloidosis=systemic amyloidosis in which amyloid [A] proteins derived from immunoglobulin light chains [L] are deposited in tissue, CI=confidence interval, KQ=Key Question, LCMM=light chain myeloma, MGUS=monoclonal gammopathy of undetermined significance, MM=multiple myeloma, nd=no data, SFLC=serum free light chain, SIFE=serum immunofixation, SPEP=serum protein electrophoresis, UIFE=urine immunofixation electrophoresis.

* Monoclonal gammopathy includes PCDs as well as other conditions such as hematological disorders associated with a monoclonal band.

Each study was rated B quality because of the retrospective design and because formal statistical comparisons and confidence intervals were not provided. All three studies compared test results with the diagnosis of disease verified by medical records on the basis of a panel of criteria. One study reported industry-associated funding and also was the only study of the three to report the demographic characteristics of the study population 31

Abadie 2006^31^ examined the diagnostic accuracy of the SFLC assay, with or without SPEP, in 312 consecutive, predominantly male veterans without a prior diagnosis of PCD. Fifteen percent of the patients were found on diagnostic testing to have a malignant PCD. The use of SPEP alone had a diagnostic sensitivity of 0.88 and a specificity of 0.98, with 15 false negatives (12 for MM and 1 each for Waldenstrom's macroglobulinemia, AL amyloidosis, and lymphoma). SPEP used in combination with the SFLC assay increased the sensitivity to 1.00 and the specificity to 0.99, although use of the SFLC assay alone showed four false negatives (two for MM and two for “potential MM”).

Piehler 2008^32^ measured SFLCs, as well as performing SPEP, in 332 patients suspected of having monoclonal gammopathy (i.e., a PCD or other conditions such as hematological disorders associated with a monoclonal band). Twenty-seven percent of patients had a PCD, including 2.1 percent with LCMM, 6.6 percent with MM, 0.6 percent with amyloidosis, and 13.6 percent with MGUS. Use of the SFLC assay plus SPEP resulted in a diagnostic sensitivity of 0.96 and specificity of 0.78; whereas SPEP alone had a sensitivity of 0.87 and specificity of 0.98.

Vermeersch 2008^33^ explored the use of the SFLC assay in 833 consecutive patients suspected of having a PCD and compared various tests and combinations of tests (Table 4). Three percent of patients had a malignant PCD and 19 percent had MGUS. The highest diagnostic sensitivity, 0.94, was achieved by using the SFLC assay plus SIFE. SIFE alone had a sensitivity of 0.92. The SFLC assay plus SPEP (with SIFE performed only if SPEP was positive, for confirmation) achieved a sensitivity of 0.82, whereas SPEP plus SIFE without the SFLC assay had a sensitivity of 0.79. SPEP plus SIFE had a specificity of 1.00, as did SIFE alone; the SFLC assay plus either SPEP (with SIFE for confirmation) or SIFE had a specificity of 0.97.

### Summary

Three retrospective studies evaluated the SFLC assay in combination with traditional tests in undiagnosed patients suspected of having a PCD. The addition of the SFLC assay to traditional tests in a diagnostic panel increased the sensitivity of the assay for detection of PCDs in all three studies (from 0.64–0.87 to 0.96–1.00 for SPEP and to 0.92–0.94 for SIFE). The statistical significance of the increase in sensitivity was not addressed in any of the studies; the effect on specificity was inconsistent. The studies were heterogeneous with regard to design and comparator, such that meta-analysis could not be performed for quantitative data synthesis. We rated the strength of evidence to evaluate the effect of adding SFLC testing to traditional testing on diagnostic performance as insufficient.

## KQ2 As compared with traditional tests, how well does the SFLC assay independently predict progression to MM in patients with MGUS?

No studies compared the use of the SFLC assay with traditional tests to determine whether the use of the SFLC assay predicts progression from MGUS to MM. Therefore, we rated the strength of evidence as insufficient for this question.

## KQ3 In patients with an existing diagnosis of PCD (MM, NSMM, or AL amyloidosis), does the use of the SFLC assay result in different treatment decisions as compared with traditional tests?

- Does the use of the SFLC assay affect the management of patients by allowing for earlier institution of specific therapies?
- Does the use of the SFLC assay influence the duration of treatment?
- Does the use of the SFLC assay influence the type of treatment (e.g., radiation therapy)?

No studies compared the use of the SFLC assay with traditional tests to determine whether treatment decisions were different with regard to timing, duration, or type of treatment. Therefore, we rated the strength of evidence as insufficient for this question.

## KQ4 In patients with an existing diagnosis of PCD (MM, NSMM, or AL amyloidosis), is the SFLC assay better than traditional tests in indicating how the patient responds to treatment and of outcomes (overall survival, disease-free survival, remission, light chain escape, and quality of life)?

### Results

Eleven studies evaluated the SFLC assay and traditional testing in parallel and examined their relationship to clinical outcomes in PCDs.13,34-42 43 No direct comparisons between the SFLC assay and traditional tests were performed. Three studies were conducted in patients with AL amyloidosis13,38,40 and eight in patients with MM.34-37,39,41-43 Three studies38,40,43 reported industry-associated funding or authorship. Nine studies were retrospective13,34-36,38-42 and one was prospective43; the remaining study37 lacked enough detail to determine the study design. Followup times varied from 3 months to 13 years, with sample sizes of 40 to 443 patients. Among studies reporting patient characteristics, the median age ranged from 54 to 72 years and the study populations were 44 to 65 percent male.

#### Patients With AL Amyloidosis

Three retrospective studies examined the SFLC assay in patients with AL amyloidosis and reported the use of SFLC assay in evaluating treatment response and predicting prognosis: Kumar 2011,^38^ Lachmann 2003, 40 and Sanchorawala 2005.^13^ These studies measured SFLC responses and paraprotein responses to treatment with traditional testing (electrophoresis or IFE) and examined their relationship to outcomes. Paraprotein reduction was usually reported as part of a “hematologically complete” response.22

The sample sizes were 66, 262, and 443 patients (Tables 5–7). Followup times were 21 months to 5 years. Kumar 2011 and Lachmann 2003 reported industry-associated funding or authorship. All three studies reported explicit diagnostic criteria. Lachmann 2003 reported enrolling referred patients; the other two studies did not describe the enrollment method. The median age of study participants was 54 to 64 years and, in the two studies with data on patient sex, one had 61 percent men and the other, 63 percent men. All three studies were rated as quality C; none of the three studies performed direct statistical comparisons of the relative strength of prediction, providing only unadjusted estimates for each predictor.

Table 5 Characteristics of studies addressing KQ4

Author Year [PMID] | Index Test/Comparator Test | Sample Size | Funding | Study Design | Enrollment Period | Followup Duration | Diagnostic Driteria | Quality Grade and Issues
AL Amyloidosis: SFLC Response to Therapy and Relationship to Outcomes
Kumar, 2011^38^ [21328431] | Post-treatment dFLC | 443 Cohort I: 347 Cohort II: 96 | Government, industry | Retrospective | nd | 72 mo | Biopsy-proven AL amyloidosis | C (retrospective, extreme selection/spectrum bias)
Kumar, 2011^38^ [21328431] | Post-treatment quantitative M protein concentrations | 443 Cohort I: 347 Cohort II: 96 | Government, industry | Retrospective | nd | 72 mo | Biopsy-proven AL amyloidosis | C (retrospective, extreme selection/spectrum bias)
Lachmann, 2003^40^ [12823348] | Post-treatment SFLC concentrations | 262 | Government, author(s) employed by industry | Retrospective | 1992–2002 | 21–29 mo | Immunohistochemically confirmed AL amyloidosis | C (retrospective, selection/spectrum bias, sample not uniformly treated)
Lachmann, 2003^40^ [12823348] | Post-treatment quantitative paraprotein concentrations | 262 | Government, author(s) employed by industry | Retrospective | 1992–2002 | 21–29 mo | Immunohistochemically confirmed AL amyloidosis | C (retrospective, selection/spectrum bias, sample not uniformly treated)
Sanchorawala, 2005^13^ [16044137] | Post-treatment SFLC concentrations | 66 | Government, academic | Retrospective | 1994–2003 | 5 yr | Histological diagnosis of AL amyloidosis with evidence of PCD and eligibility for high-dose melphalan SCT treatment in clinical protocols | C (retrospective, small sample size)
Sanchorawala, 2005^13^ [16044137] | Hematological complete response (defined by EBMT44; includes M protein response) | 66 | Government, academic | Retrospective | 1994–2003 | 5 yr | Histological diagnosis of AL amyloidosis with evidence of PCD and eligibility for high-dose melphalan SCT treatment in clinical protocols | C (retrospective, small sample size)
MM: Assessment and Prediction of Treatment Response
Dispenzieri, 2008^34^ [18364469] | SFLC response | 399 | Government | Retrospective | 1988–1992 | 13 yr | M protein ≥10 g/L or urine monoclonal FLC >200 mg in 24 hr or serially measurable soft tissue plasmacytoma or bone marrow plasmacytosis ≥20% | B (retrospective without adjustment)
Dispenzieri, 2008^34^ [18364469] | SPEP, UPEP | 399 | Government | Retrospective | 1988–1992 | 13 yr | M protein ≥10 g/L or urine monoclonal FLC >200 mg in 24 hr or serially measurable soft tissue plasmacytoma or bone marrow plasmacytosis ≥20% | B (retrospective without adjustment)
Dytfeld, 2011^43^ [21699382] | Percent reduction in involved FLC concentrations Normalization of FLC ratio | 40 | Industry, author(s) employed by industry, manuscript reviewed by industry | Prospective | 2005–2007 | 45 mo | Histologically confirmed diagnosis of MM | C (small sample size, sample not uniformly treated)
Dytfeld, 2011^43^ [21699382] | Percent reduction in serum and urine M protein concentrations | 40 | Industry, author(s) employed by industry, manuscript reviewed by industry | Prospective | 2005–2007 | 45 mo | Histologically confirmed diagnosis of MM | C (small sample size, sample not uniformly treated)
Khoriaty, 2010^36^ [20223721] | SFLC concentrations | 89 (43 with evaluable disease) | nd | Retrospective | 2004–2006 | 40 mo | nd | C (small sample size, retrospective without adjustment)
Khoriaty, 2010^36^ [20223721] | IMWG criteria | 89 (43 with evaluable disease) | nd | Retrospective | 2004–2006 | 40 mo | nd | C (small sample size, retrospective without adjustment)
Kroger, 2010^37^ [2043663] | SFLC response | 52 | nd | Unclear | 2003–2008 | 3 mo | nd | C (letter to the editor with limited information, small sample size, few details about SFLC response criteria and study design, limited data available)
Kroger, 2010^37^ [2043663] | SIFE or UIFE | 52 | nd | Unclear | 2003–2008 | 3 mo | nd | C (letter to the editor with limited information, small sample size, few details about SFLC response criteria and study design, limited data available)
Paiva, 2011^42^ [21402611] | SFLC ratio normalization (stringent complete response) | 102 | Nonprofit foundation | Retrospective | nd | 32 mo | nd | C (retrospective without adjustment, potential selection bias because inclusion was based on availability of serum samples)
Paiva, 2011^42^ [21402611] | Immunophenotypic response | 102 | Nonprofit foundation | Retrospective | nd | 32 mo | nd | C (retrospective without adjustment, potential selection bias because inclusion was based on availability of serum samples)
MM: Relationship Between Baseline SFLC Ratios and Survival
Kyrtsonis, 2007^39^ [17408464] | SFLC ratio | 94 | Nonprofit foundation | Retrospective | nd | 33 mo | nd | C (limited information about patient recruitment and study design, small sample size)
Kyrtsonis, 2007^39^ [17408464] | ISS stages 1–3; Durie–Salmon stages I–III^*^ | 94 | Nonprofit foundation | Retrospective | nd | 33 mo | nd | C (limited information about patient recruitment and study design, small sample size)
van Rhee, 2007^41^ [17416735] | Baseline SFLC concentrations | 303 | Government | Retrospective | nd | 21 mo | nd | B (retrospective with adjustment)
van Rhee, 2007^41^ [17416735] | Baseline concentrations of serum and urine M protein | 303 | Government | Retrospective | nd | 21 mo | nd | B (retrospective with adjustment)
MM: Relationship Between Post-Treatment SFLC Ratios and Survival
Giarin,2009^35^ [19520760] | SFLC ratio | 203 | Government | Retrospective | 1995–2006 | 37 mo | nd | B (retrospective without adjustment)
Giarin,2009^35^ [19520760] | Total kappa/lambda ratio, SIFE | 203 | Government | Retrospective | 1995–2006 | 37 mo | nd | B (retrospective without adjustment)
Paiva, 2011^42^ [21402611] | SFLC ratio normalization (stringent complete response) Immunophenotypic response | 102 | Nonprofit foundation | Retrospective | nd | 32 mo | nd | C (retrospective without adjustment, potential selection bias because inclusion was based on availability of serum samples)
van Rhee, 2007^41^ [17416735] | SFLC response tertiles | 303 | Government | Retrospective | nd | 21 mo | nd | B (retrospective with adjustment)
van Rhee, 2007^41^ [17416735] | Percent reduction of serum and urine M protein concentrations | 303 | Government | Retrospective | nd | 21 mo | nd | B (retrospective with adjustment)

AL amyloidosis=systemic amyloidosis in which amyloid [A] proteins derived from immunoglobulin light chains [L] are deposited in tissue, dFLC=difference in the levels of the involved free light chain (FLC, either kappa or gamma) and the other (uninvolved FLC), EBMT=European Group for Blood and Bone Marrow Transplant, IMWG=International Myeloma Working Group, ISS=International Staging System, KQ=Key Question, MM=multiple myeloma, mo=months, nd=no data, PCD=plasma cell dyscrasia, SCT=stem cell transplantation, SFLC=serum free light chain, SIFE=serum immunofixation electrophoresis, SPEP=serum protein electrophoresis, UIFE=urine protein electrophoresis, UPEP=urine protein electrophoresis, yr=years.

* ISS classification incorporates concentrations of serum albumin and β2 microglobulin.45 The Durie–Salmon staging system classification incorporates concentrations of serum and urinary paraproteins.46

Table 6 Characteristics of patients in studies addressing KQ4

Author Year [PMID] | Enrollment Method | Median Age (yr) | Percent Male | Population Description and Inclusion Criteria
AL Amyloidosis
Kumar, 2011^38^ [21328431] | nd | Cohort I: 58 Cohort II: 64 | Cohort I: 57 Cohort II: 64 | AL amyloidosis, with 347 patients receiving autologous SCT and 96 receiving melphalan and dexamethasone
Lachmann, 2003^40^ [12823348] | Referred patients | 54–64 | nd | Systemic AL amyloidosis, no prior chemotherapy, excluding those with concurrent MM or other malignant B-cell dyscrasias
Sanchorawala, 2005^13^ [16044137] | nd | 60 | 63 | Receipt of high-dose intravenous melphalan and autologous SCT
MM: Assessment and Prediction of Treatment Response
Dispenzieri, 2008^34^ [18364469] | Patients enrolled in a previous treatment trial (E9486) | 63 | 65 | Diagnosed with MM, enrollment in a previously published treatment trial, measurable disease in absence of treatment, pre- and post-treatment serum samples available
Dytfeld, 2011^43^ [21699382] | nd | nd | nd | Diagnosed with MM, receiving VDD treatment for newly diagnosed, histologically confirmed MM
Khoriaty, 2010^36^ [20223721] | nd | 61 | 65 | Diagnosed with MM (relapsed or newly diagnosed), treatment at the Cleveland Clinic Taussig Cancer Institute, enrolled in other trials, with SFLC measurement every 4 weeks from April 2004 to December 2006 (Only 43 patients [48%] had evaluable disease)
Kroger, 2010^37^ [2043663] | nd | nd | nd | Diagnosed with MM, complete response between January 2003 and December 2008 for at least 3 mo, negative SIFE or UIFE test
Paiva, 2011^42^ [21402611] | Patients enrolled in a previous trial (GEM05>65y PETHEMA/GEM trial) | 72 | 44 | Diagnosed with MM, enrolled in a previous treatment trial, who achieved at least a partial response with 70% reduction in M protein after the six planned induction cycles; patients with available serum samples
MM: Relationship Between Baseline SFLC Ratios and Survival
Kyrtsonis, 2007^39^ [17408464] | nd | 32% >65 yr | 45 | Diagnosed with MM, with or without treatment
van Rhee, 2007^41^ [17416735] | Patients enrolled in a previous trial (Total Therapy 3) | nd | 64 | Newly diagnosed MM, participation in a tandem autotransplantation trial
MM: Relationship Between Post-Treatment SFLC Ratios and Survival
Giarin, 2009^35^ [19520760] | nd | 56 | 55 | Newly diagnosed MM between July 1995 and February 2006, receipt of autologous or autologous and allogeneic SCT
Paiva, 2011^42^ [21402611] | Patients enrolled in a previous trial (GEM05>65y PETHEMA/GEM trial) | 72 | 44 | Diagnosed with MM, enrolled in a previous treatment trial, achievement of at least a partial response with 70% reduction in M protein after the six planned induction cycles; patients with available serum samples
van Rhee, 2007^41^ [17416735] | Patients enrolled in a previous trial (Total Therapy 3) | nd | 64 | Newly diagnosed MM, participation in a tandem autotransplantation trial

AL amyloidosis=systemic amyloidosis in which amyloid [A] proteins derived from immunoglobulin light chains [L] are deposited in tissue, KQ=Key Question, MM=multiple myeloma, nd=no data, SCT=stem cell transplantation, SFLC=serum free light chain, SIFE=serum immunofixation electrophoresis, UIFE=urine immunofixation electrophoresis, VDD=bortezomib, pegylated liposomal doxorubicin, and dexamethasone, yr=years.

Table 7 Results of studies addressing KQ4

Author Year [PMID] | Sample Size | Index Test/Comparator Test | Results
AL Amyloidosis
Kumar, 2011^38^ [21328431] | 443 Cohort I: 347 Cohort II: 96 | Post-treatment dFLC | dFLC (vs. SPEP) significantly affected overall survival (p<0.0001) ≤90% reduction in dFLC best predicted survival at 3 or 5 yr; median overall survival was not reached among those with a ≤90% reduction but was 37.4 months with >90% decrease (p <0.001)
Kumar, 2011^38^ [21328431] | 443 Cohort I: 347 Cohort II: 96 | Post-treatment quantitative M protein concentrations
Lachmann, 2003^40^ [12823348] | 262 | Post-treatment SFLC concentrations | 86 patients with abnormal FLC concentration falling >50%after chemotherapy had 88% 5-year survival vs. only 39% among those with lesser reduction (p <0.0001) Amyloidogenic FLC reduction >50% associated with survival benefit, regardless of type of chemotherapy Amyloid load correlated with changes in SFLC concentration (p <0.0001). Among 73 patients with serially quantifiable serum paraprotein, survival was better in those whose concentration fell by >50% vs. those whose fell by ≤50% (p <0.05).
Lachmann, 2003^40^ [12823348] | 262 | Post-treatment quantitative paraprotein concentrations
Sanchorawala, 2005^13^ [16044137] | 66 | Post-treatment SFLC concentrations | Death: % (number/total number) Complete vs. noncomplete response: 4% (1/27) vs. 18% (7/39) (p-value not available) FLC response >90% vs. ≤90%: 6% (2/35) vs. 19% (6/31) (p value not available) Clinical improvement: % (number/total number) Complete vs. noncomplete response: 96% (26/27) vs. 67% (26/39) (p=0.047) FLC response >90% vs. ≤90%: 97% (34/35) vs. 58% (18/31) (p value not available) FLC response and measures of hematological response complementary
Sanchorawala, 2005^13^ [16044137] | 66 | Hematological complete response (defined by EBMT criteria44; includes M protein response)
MM: Assessment and Prediction of Treatment Response
Dispenzieri, 2008^34^ [18364469] | 139 | SFLC response | After 2 months of therapy, 23% had achieved a paraprotein response in SPEP and/or UPEP compared with 62% who achieved an FLC response 85% of FLC responders developed overall objective response vs. 51% of FLC nonresponders (p<0.001) Prediction of ECOG overall objective response status^*^: 2-mo FLC response: sensitivity 69%, specificity 73%, risk 0.3; 2-mo paraprotein response: sensitivity 34%, specificity 98%, risk 0.5; p <0.001
Dispenzieri, 2008^34^ [18364469] | 139 | SPEP, UPEP
Dytfeld, 2011^43^ [21699382] | 40 | Percent reduction in involved FLC concentrations Normalization of SFLC ratio | A novel FLC and M protein–based prognostic model predicts that ≥90% reduction of serum M protein or ≥90% reduction of involved FLC or normalization of SFLC ratio predicted ≥VGPR with 92% sensitivity and 93% specificity after two cycles of treatment with VDD, with sensitivity increasing to 96% after three cycles of treatment. Neither the rate of M protein decline nor the decline of involved FLC independently predicted VGPR at the end of six cycles of VDD (at 90% sensitivity and specificity). When the involved was replaced by urine M protein in the predictive model, sensitivity, specificity, and predictive value were all <90%.
Dytfeld, 2011^43^ [21699382] | 40 | Percent reduction in serum and urine M protein concentrations
Khoriaty, 2010^36^ [20223721] | 43 (those with evaluable disease) | SFLC ratio | For SFLC assay prediction of response to treatment (95% CI): Sensitivity: 81% (51 to 94%) Specificity: 83% (65 to 92%) PPV: 64% (38 to 83%) NPV: 92% (68 to 98%) For SFLC assay prediction of progression (95% CI): Sensitivity: 93% (68 to 98%) Specificity: 80% (62 to 91%) PPV: 72% (49 to 87%) NPV: 95% (78 to 99%)
Khoriaty, 2010^36^ [20223721] | 43 (those with evaluable disease) | IMWG criteria27
Kroger, 2010^37^ [2043663] | 52 | SFLC | 51/52 (98%) patients had normal SFLC ratio In the subgroup of 10 patients who relapsed, 9 had abnormal SFLC ratio before having a positive IFE test
Kroger, 2010^37^ [2043663] | 52 | SIFE or UIFE | 51/52 (98%) patients had normal SFLC ratio In the subgroup of 10 patients who relapsed, 9 had abnormal SFLC ratio before having a positive IFE test
Paiva, 2011^42^ [21402611] | 102 | SFLC ratio | 22 patients had discordant results of treatment response between SFLC ratio definition and immunophenotypic response definition: 6 had abnormal SFLC ratio but achieved immunophenotypic response 5 had normal SFLC ratio but no complete response because immunofixation was positive 11 had normal SFLC ratio and negative immunofixation but no immunophenotypic response
Paiva, 2011^42^ [21402611] | 102 | Immunophenotypic response
MM: Relationship Between Baseline SFLC Ratios and Survival
Kyrtsonis, 2007^39^ [17408464] | 94 | SFLC ratio | 3- and 5-year disease-specific survival rates, 94% and 82%, respectively, with SFLC ratio below median (vs. 58% and 30%, respectively, with SFLC ratio above the median; p=0.0001) Durie–Salmon and ISS staging were independent predictors of survival (p <0.0001 for both)
Kyrtsonis, 2007^39^ [17408464] | 94 | ISS stages 1–3, Durie–Salmon stages I–III^**^
van Rhee, 2007^41^ [17416735] | 303 | Baseline SFLC concentrations | Rate of near-complete response to induction therapy higher among patients with baseline SFLC >75 mg/dL than patients with baseline SFLC ≤75 mg/dL (37% vs. 20%, p=0.002). Adjusted HR (95% CI) for overall survival: Baseline SFLC >75 (vs. ≤75) mg/dL: 2.43 (1.18 to 5.01), p=0.016 Adjusted HR (95% CI) for event-free survival: Baseline SFLC >75 (vs. ≤75) mg/dL: 2.40 (1.26 to 4.57), p=0.008 Baseline concentrations of standard serum and urine M protein did not identify prognostic subgroups
van Rhee, 2007^41^ [17416735] | 303 | Baseline concentrations of serum and urine M protein
MM: Relationship Between Post-Treatment SFLC Ratios and Survival
Giarin, 2009^35^ [19520760] | 203 | SFLC ratio | 3 mo after SCT, overall and event-free survival did not differ significantly between patients with and those without normal SFLC ratio or between patients with and those without normal (negative) SIFE test. Longer event-free but not overall survival significantly associated with normal SFLC ratio at 3 mo post SCT (HR, 0.68; 95% CI, 0.50 to 0.93, p=0.02)
Giarin, 2009^35^ [19520760] | 203 | Total kappa/lambda ratio, SIFE
Paiva, 2011^42^ [21402611] | 102 | SFLC ratio normalization (stringent complete response) | Among 44 patients with negative immunofixation (conventional complete response), rate of 3-year progression-free survival did not differ between patients with normal SFLC ratio and patients with abnormal SFLC ratio (69% vs. 64%, p=0.4). Similarly, time to progression and overall survival did not differ between groups (p=0.2 and p=0.9, respectively). Among 78 patients with positive immunofixation, rate of 3-year progression-free survival, time to progression, and overall survival did not significantly differ between patients with normal and abnormal SFLC ratios (p=0.2, p=0.1, p=0.3, respectively).
Paiva, 2011^42^ [21402611] | 102 | Immunophenotypic response
van Rhee, 2007^41^ [17416735] | 303 | SFLC response tertiles | Rate of near-complete response to induction therapy higher among patients with baseline SFLC >75 mg/dL than patients with baseline SFLC ≤75 mg/dL (37% vs. 20%, p=0.002). Adjusted HR (95% CI) for overall survival: Top tertile (vs. lower two tertiles) in percent SFLC reduction after cycle 2: 2.15 (1.03 to 4.47), p=0.041 Top tertile (vs. lower two tertiles) in percent SFLC reduction after transplantation: 2.24 (1.03 to 4.87), p=0.042 Baseline SFLC >75 (vs. ≤75) mg/dL: 2.43 (1.18 to 5.01), p=0.016 Adjusted HR (95% CI) for event-free survival poorer with higher percent reduction in SFLC level: Top tertile(vs. lower two tertiles) in percent SFLC reduction after cycle 2: 1.96 (1.03 to 3.74), p=0.041 Top tertile (vs. lower two tertiles) in percent SFLC reduction after transplantation: 2.01 (1.02 to 3.97), p=0.045 Reductions in serum and urine M protein values not significantly associated with overall or event-free survival
van Rhee, 2007^41^ [17416735] | 303 | Percent reduction of serum and urine M protein concentrations

AL amyloidosis=systemic amyloidosis in which amyloid [A] proteins derived from immunoglobulin light chains [L] are deposited in tissue, CI=confidence interval, dFLC=difference in the levels of the involved free light chain (FLC, either kappa or gamma) and the other (uninvolved FLC), EBMT=European Group for Blood and Bone Marrow Transplant, ECOG=Eastern Cooperative Oncology Group, FLC=free light chain, HR=hazard ratio, IFE=immunofixation electrophoresis, IMWG=International Myeloma Working Group, ISS=International Staging System, KQ=Key Question, MM=multiple myeloma, mo=months, NPV=negative predictive value, PPV=positive predictive value, SCT=stem cell transplantation, SFLC=serum free light chain, SIFE=serum immunofixation electrophoresis, SPEP=serum protein electrophoresis, UIFE=urine immunofixation electrophoresis, UPEP=urine protein electrophoresis, VDD=bortezomib, pegylated liposomal doxorubicin, VGPR=very good partial response, yr=years.

* Standard ECOG response criteria are as follows: 50 percent decrease in serum M protein or, in patients lacking a serum M protein measurement, a 90 percent decrease in 24-hour urine M protein.34

** ISS classification incorporates concentrations of serum albumin and β2 microglobulin.45 The Durie–Salmon staging system classification incorporates concentrations of serum and urinary paraproteins.46

All three studies showed that patients with greater reductions in abnormal SFLC concentrations (a >50 percent reduction40 or >90 percent reduction,13,38 vs. lesser reductions) after treatment (either chemotherapy or stem-cell transplantation) had better survival outcomes.

Although Kumar 2011^38^ did not find quantitative paraprotein concentrations to be a good predictor (unlike SFLC concentrations), Lachmann 2003^40^ found the paraprotein concentration to be significantly related to survival; however, the relationship seemed to be weaker than that of SFLC reduction to survival. In Kumar 2011, some patients with PCD did not have “measurable disease,” (i.e., they did not have elevated SFLC concentrations before treatment), which precluded use of the SFLC assay as a marker of disease and treatment response, limiting the assay's utility. Sanchorwala 2005^13^ found that a reduction in SFLC concentration by more than 90 percent and achievement of a complete response were both predictive of a lower mortality and both provided independent predictive information.

##### Summary for AL Amyloidosis

Although the three studies reported that the SFLC assay may aid in assessing treatment response and monitoring outcomes in AL amyloidosis patients, no direct comparisons with traditional tests (electrophoresis or IFE) were performed. All three studies were rated as quality C, owing to limitations in study design, including selection/spectrum bias as well as (in one study) small sample size. Overall, because of a lack of direct comparisons and poor study quality, current evidence on the effectiveness of the SFLC assay compared with traditional tests for assessment of treatment response and outcome is inconclusive. The strength of evidence underlying this comparison was therefore rated as insufficient.

#### Patients With MM

Eight studies34-37,39,41 42,43 enrolled patients with MM and compared the use of SFLC assay and other traditional tests in evaluating treatment response and predicting prognosis (Tables 5–7). Six of the eight—Dispenzieri 2008,^34^ Giarin 2009,^35^ Khoriaty 2010,^36^ van Rhee 2007,^41^ Kyrtsonis 2007,^39^, and Paiva 2011^42^—were retrospective analyses of cohorts; one study, Dytfeld 2011,^43^ was prospective; and study design was not specified in the remaining study, Kroger 2010.^37^ Sample size ranged from 40 to 303, and median followup duration was 3 months to 13 years. Study quality was graded as B in three of the eight studies, owing to retrospective designs without adjustments for potential confounders,34,35,41 and C in the other five studies, owing to small sample sizes, limited information about study design, and/or potential selection bias.36,37,39,42,43 None of the three B-quality studies performed direct statistical comparisons of relative strength of prediction. The three outcome categories covered in the studies are discussed in the next paragraphs.

##### Assessment and Prediction of Treatment Response

Four studies34,36, 37,42 addressed the use of SFLC assay in the assessment of treatment response and one study43 addressed the prediction of treatment response. The traditional test comparators that were also used to assess treatment response (in parallel with the SFLC assay) differed in each study (i.e., SPEP, UPEP, total kappa/lambda ratio measured by nephelometry, bone marrow evaluation with immunophenotyping, or standard response criteria [e.g., from IMWG]).

Of the four studies that used SFLC test results to assess treatment response, one study, of C quality, found that 22 of 102 patients had discordant findings regarding achievement of a treatment response after induction therapy, defined according to the SFLC ratio and the immunophenotypic response.42 Another study, of B quality, found that after 2 months of therapy, treatment response was achieved by 23 percent of 139 patients using the paraprotein definition, compared with 62 percent using the SFLC definition.34 In a C-quality study, the majority (27 of 43 patients) achieved treatment response as defined by both M protein criteria and SFLC criteria at the same time; SFLC response occurred earlier than M protein response in eight other patients.36 A fourth study37 of unclear design reported an abnormal SFLC ratio before relapse and a positive IFE test in 9 of a subgroup of 10 patients. The quality of this study was rated as C because of the limited information about study design, SFLC response definitions, and results.

Only 1 study, of C quality, reported data on prediction of treatment response.43 Patients received VDD (bortezomib, pegylated liposomal doxorubicin, and dexamethasone) treatment for newly diagnosed, histologically confirmed MM. An SFLC and M protein–based prognostic model predicted that either a 90 percent or greater reduction in serum M protein level or involved SFLC level, or normalization of the SFLC ratio, predicted a very good partial response (VGPR) or better response with 92 percent sensitivity and 93 percent specificity after two cycles of VDD treatment. Sensitivity increased to 96 percent after three cycles of VDD treatment. Taking into account the heterogeneity of MM and its spectrum of M protein presentations, measurements of both the involved SFLC and M protein were needed to fully monitor response to treatment. Neither the rate of decline in M protein or involved SFLC concentration independently predicted VGPR at the end of six cycles of VDD (at 90 percent sensitivity and specificity). When the involved SFLC was replaced by urine M protein in the predictive model, the sensitivity, specificity, and predictive value were all less than 90 percent.

##### Relationship Between Baseline SFLC Measurements and Survival

Two studies examined the relationship of baseline SFLC concentrations and survival; one followed 303 patients for 21 months and included concomitant evaluation of the predictive ability of traditional testing (in the form of measurement of baseline concentrations of serum and urine M protein),41 whereas the other followed 94 patients for 33 months and incorporated the clinical Durie–Salmon staging system and the International Staging System (ISS).39 In the former study, of B quality, the top tertile of SFLC concentrations (>75 mg/dL) were considered the risk category,41 whereas in the latter study, of C quality, patients were stratified according to whether the SFLC ratio was above or below the median (with the ratio calculated using the involved SFLC in the numerator, for a monotonic distribution).39 In both studies, patients with higher SFLC concentrations or ratio had significantly lower survival rates than did patients with lower SFLC concentrations or ratio. The former study did not find serum or urine M protein concentrations to be predictive of survival and reported significantly poorer overall and event-free survival rates among patients with a baseline SFLC level of greater than 75 mg/dL (vs. ≤75 mg/dL; p=0.016 and p=0.008, respectively).41 The latter study reported that while Durie–Salmon and ISS staging were independent predictors (both p<0.0001), an abnormal SFLC ratio was also significantly associated with 3- and 5-year disease-specific survival rates (p=0.0001).39

##### Relationship Between Post-Treatment SFLC Measurements and Survival

Three studies examined the relationship between post-treatment SFLC ratios and survival.35,41,42 One study42 of C quality analyzed the SFLC ratios after induction therapy among a subset of 102 patients enrolled in a previous trial. After stratification of patients on the basis of immunofixation status, the 3-year progression-free survival rate, time to progression, and overall survival did not differ between patients with normal and abnormal SFLC ratios post-treatment.42

A second study,35 of B quality, analyzed immunofixation results and SFLC ratios after stem-cell transplantation among 202 patients. Overall and event-free survival did not differ between patients with and those without a normal SFLC ratio or between patients with and those without a normal SIFE test.35 However, this study also reported that a normal SFLC ratio at 3 months post treatment was significantly associated with longer event-free survival (p=0.02) but not with overall survival (p=NS).

In a third study of 303 patients,41 also of B quality, patients with a percent reduction in SFLC concentration in the top tertile after transplantation had nearly twice the risk of death—that is, hazard ratios greater than 2 for overall or event-free survival—than patients with less of a percent reduction (after adjustment for serum lactate dehydrogenase concentration and cytogenetic abnormalities), despite a paradoxically better response to induction therapy. However, there was no significant relationship between the tertiles of percent reductions in serum and urine M protein values and overall or event-free survival.

##### Summary for MM

Eight studies reported on the use of the SFLC assay and traditional tests in measuring treatment response and predicting prognosis in patients with MM. However, none of the studies formally compared the predictive capability of the SFLC assay with that of traditional tests. Most (75 percent) were retrospective cohort studies, and only 3 were of quality B (with the rest being quality C). The studies were heterogeneous with respect to population, intervention (diagnostic test/disease monitoring), and comparator as well as degree of adjustment for confounders. Taken together, these factors limit the conclusions that can be drawn about the definitive use of the SFLC assay in prognosis prediction, and the strength of evidence was rated as insufficient for comparisons with traditional testing in patients with MM.

## KQ5 In patients with an existing diagnosis of PCD (MM, NSMM, or AL amyloidosis), does the use of the SFLC assay reduce the need for other diagnostic tests (e.g., bone marrow biopsy)?

### Results

We identified one C-quality retrospective cohort study assessing the need for bone marrow examination, with the SFLC assay used to define the completeness of response to treatment: Chee 2009^47^ (Tables 8–10). As currently defined in the European Group for Blood and Marrow Transplantation and IMWG uniform response criteria, a complete response in a patient with MM requires a bone marrow examination showing less than 5 percent plasma cells, in addition to negative SIFE and UIFE results; the addition of normalization of the SFLC ratio defines stringently complete remission.22,27

Table 8 Characteristics of studies addressing KQ5

Author Year [PMID] | Index Test | Funding | Study Design | Enrollment Period | Followup Duration | Diagnostic Criteria | Quality Grade and Issues
Chee 2009,^47^ [19641191] | SFLC ratio | Government | Retrospective cohort | nd | 1995–?? | MM, measurable M protein concentrations at baseline (serum M protein ≤1 g/dL or urine M protein ≤0.2 g/day), and since start of study, negative SIFE and UIFE with concomitant bone marrow aspirate or biopsy and normal SFLC ratio (with all tests performed within 30 days of each other) | C (retrospective, small convenience sample)

KQ=Key Question, MM=multiple myeloma, nd=no data, SFLC=serum free light chain, SIFE=serum immunofixation electrophoresis, UIFE=urine immunofixation electrophoresis.

Table 9 Characteristics of patients in studies addressing KQ5

Author Year [PMID] | Enrollment Method | Sample Size | Median Age (yr) | Sex | Exclusion Criteria
Chee 2009,^47^ [19641191] | Selected patients | 92 With negative IFE, including 29 with normalized SFLC ratio Treatment: Bone marrow transplantation, 51 Chemotherapy, 26 Second-line therapy, 10 Unknown, 5 | 59 | nd | Not specified

IFE=immunofixation electrophoresis, KQ=Key Question, nd=no data, SFLC=serum free light chain, yr=years.

Table 10 Results of studies addressing KQ5

Author Year [PMID] | Index Test | Comparator Test and Definition | Sample Size | Results
Chee 2009,^47^ [19641191] | Normal SFLC ratio | IFE test followed by bone marrow aspirate or biopsy, performed within 30 days of SFLC assay | 92 with negative IFE, including 29 with normalized SFLC ratio | 14% of patients with negative IFE had ≥5% plasma cells in bone marrow. 10% of patients with normal SFLC ratio had >5% plasma cells in bone marrow. Addition of normal SFLC ratio to negative serum and urine IFE appears insufficient to confirm complete response accurately in the absence of a bone marrow aspirate or biopsy using standard EBMT/IMWG criteria. SFLC ratio does not eliminate the need for bone marrow for quantifying plasma cells for assessment of response in MM.

EBMT=European Group for Blood and Bone Marrow Transplant, IFE=immunofixation electrophoresis, IMWG=International Myeloma Working Group, KQ=Key Question, MM=multiple myeloma, SFLC=serum free light chain.

Chee 2009 enrolled 92 patients with MM who achieved negative SIFE and UIFE tests after therapy and had a bone marrow aspirate or biopsy performed within 30 days before or after those tests. A subgroup of 29 patients also had data on the SFLC ratio; among those whose ratio normalized, the percentage of clonal plasma cells in the bone marrow was examined. Fourteen percent of patients with a negative IFE test had more than 5 percent plasma cells in bone marrow, as did 10 percent of patients with a normal SFLC ratio. Among patients with IFE-negative status, those with less than 5 percent plasma cells in the marrow had improved overall survival compared with those with 5 percent or more plasma cells (6.2 years vs. 2.3 years, respectively; p <0.01).

### Summary

A single study was found that addressed whether IFE or SFLC testing would reduce the need for other diagnostic tests such as bone marrow examination; the authors concluded that it was not possible to eliminate such tests. Owing to the preliminary nature of the data, we rated the strength of evidence as insufficient for addressing this question.