# References

1 Kyle RA, Rajkumar SV. Epidemiology of the plasma-cell disorders. Best Pract Res Clin Haematol. 2007;20:637-64. [pmid: 18070711].
2 Ries LAG, Harkins D, Krapcho M, et al. SEER cancer statistics review, 1975-2003. NCI. Bethesda, MD. 2005. http://seer.cancer.gov/csr/1975_2003.
3 Jemal A, Siegel R, Ward E, et al. Cancer Statistics, 2007. CA: A Cancer Journal for Clinicians. 2007;57(1):43-66. [pmid: 17237035].
4 Katzel JA, Hari P, Vesole DH. Multiple Myeloma: Charging Toward a Bright Future. CA: A Cancer Journal for Clinicians. 2007;57(5):301-18. [pmid: 17855486].
5 Cook R. An economic perspective on treatment options in multiple myeloma. Managed Care Oncol. 2007;2007(Spring):10-12.
6 Messori A, Trippoli S, Santarlasci B. Pharmacotherapy of multiple myeloma: an economic perspective. Expert Opin Pharmacother. Apr. 1. 2003;4(4):515-24. [pmid: 12667114].
7 Bradwell AR, Carr-Smith HD, Mead GP, et al. Highly sensitive, automated immunoassay for immunoglobulin free light chains in serum and urine. Clin Chem. Apr. 2001;47(4):673-80. [pmid: 11274017].
8 Rajkumar SV. Recognition of monoclonal proteins. Kyle RA, Connor RF, editors. UpToDate. Waltham. UpToDate. 2011.
9 Katzmann JA. Serum free light chains: quantitation and clinical utility in assessing monoclonal gammopathies. Clin Lab News. Jun. June. 2006:12-14.
10 Rajkumar SV. Clinical features, laboratory manifestations, and diagnosis of multiple myeloma. Basow DS, editor. UpToDate. Waltham. UpToDate. 2011.
11 Dispenzieri A, Kyle R, Merlini G, et al. International Myeloma Working Group guidelines for serum-free light chain analysis in multiple myeloma and related disorders. [Review] [43 refs]. Leukemia. Feb. 2009;23(2):215-24. [pmid: 19020545].
12 Mead GP, Carr-Smith HD, Drayson MT, et al. Serum free light chains for monitoring multiple myeloma. British Journal of Haematology. Aug. 2004;126(3):348-54. [pmid: 15257706].
13 Sanchorawala V, Seldin DC, Magnani B, et al. Serum free light-chain responses after high-dose intravenous melphalan and autologous stem cell transplantation for AL (primary) amyloidosis. Bone Marrow Transplantation. Oct. 2005;36(7):597-600. [pmid: 16044137].
14 Kyle RA, Durie BGM, Rajkumar SV, et al. Monoclonal gammopathy of undetermined significance (MGUS) and smoldering (asymptomatic) multiple myeloma: IMWG consensus perspectives risk factors for progression and guidelines for monitoring and management. Leukemia. Jun. 2010;24(6):1121-27. [pmid: 20410922].
15 Bradwell AR. Serum free light chain measurements move to center stage. Clin Chem. May. 2005;51(5):805-07. [pmid: 15855664].
16 Whitlock EP, Lopez SA, Chang S, et al. AHRQ Series Paper 3: Identifying, selecting, and refining topics for comparative effectiveness systematic reviews: AHRQ and the Effective Health-Care program. J Clin Epidemiol. 2010;63:491-501. [pmid: 19540721].
17 Dispenzieri A, Katzmann JA, Kyle RA, et al. Prevalence and risk of progression of light-chain monoclonal gammopathy of undetermined significance: a retrospective population-based cohort study. [Erratum appears in Lancet. 2010 Jul 31;376(9738):332]. Lancet. May. 15. 2010;375(9727):1721-28. [pmid: 20472173].
18 Rajkumar SV, Kyle RA, Therneau TM, et al. Serum free light chain ratio is an independent risk factor for progression in monoclonal gammopathy of undetermined significance. Blood. Aug. 1. 2005;106(3):812-17. [pmid: 15855274].
19 Dispenzieri A, Lacy MQ, Katzmann JA, et al. Absolute values of immunoglobulin free light chains are prognostic in patients with primary systemic amyloidosis undergoing peripheral blood stem cell transplantation. Blood. Apr. 15. 2006;107(8):3378-83. [pmid: 16397135].
20 Kumar S, Dispenzieri A, Katzmann JA, et al. Serum immunoglobulin free light-chain measurement in primary amyloidosis: prognostic value and correlations with clinical features. Blood. Dec. 9. 2010;116(24):5126-29. [pmid: 20798235].
21 Palladini G, Dispenzieri A, Gertz MAA, et al. Validation of the criteria of response to treatment in AL amyloidosis. American Society of Hematology Annual Meeting Abstracts. 2010;116:1364.
22 Gertz MA, Comenzo R, Falk RH, et al. Definition of organ involvement and treatment response in immunoglobulin light chain amyloidosis (AL): a consensus opinion from the 10th International Symposium on Amyloid and Amyloidosis, Tours, France, 18-22 April 2004. [Review]. American Journal of Hematology. Aug. 2005;79(4):319-28. [pmid: 16044444].
23 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. 2011.
24 Agency for Healthcare Research and Quality. Methods Guide for Medical Test Reviews. Agency for Healthcare Research and Quality. Rockville, MD. 2010. www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?productid=558&pageaction=displayproduct.
25 Wallace BC, Trikalinos TA, Lau J, et al. Semi-automated screening of biomedical citations for systematic reviews. BMC Bioinformatics. 2010;11:55. [pmid: 20102628].
26 Elliott BM, Peti S, Osman K, et al. Combining FDG-PET/CT with laboratory data yields superior results for prediction of relapse in multiple myeloma. European Journal of Haematology. Apr. 2011;86(4):289-98. [pmid: 21198866].
27 Durie BG, Harousseau JL, Miguel JS, et al. International uniform response criteria for multiple myeloma. [Erratum appears in Leukemia. 2007 May;21(5):1134].[Erratum appears in Leukemia. 2006 Dec;20(12):2220]. Leukemia. Sep. 2006;20(9):1467-73. [pmid: 16855634].
28 Atkins D, Eccles M, Flottorp S, et al. Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Services Research. 2004;4(1):38. Dec. 22. [pmid: 15615589].
29 West S, King V, Carey TS, et al. Systems to Rate the Strength of Scientific Evidence Evidence. Report/Technology Assessment No. 47 (Prepared by the Research Triangle Institute-University of North Carolina Evidence-based Practice Center under Contract No. 290-97-0011). 2002.
30 Jaeschke R, Guyatt GH, Sackett DL. Users' guides to the medical literature. III. How to use an article about a diagnostic test. B. What are the results and will they help me in caring for my patients? The Evidence-Based Medicine Working Group. JAMA. Mar. 2. 1994;271(9):703-07. [pmid: 8309035].
31 Abadie JM, Bankson DD. Assessment of serum free light chain assays for plasma cell disorder screening in a Veterans Affairs population. Annals of Clinical & Laboratory Science. 2006;36(2):157-62. [pmid: 16682511].
32 Piehler AP, Gulbrandsen N, Kierulf P, et al. Quantitation of serum free light chains in combination with protein electrophoresis and clinical information for diagnosing multiple myeloma in a general hospital population. Clin Chem. Nov. 2008;54(11):1823-30. [pmid: 18801937].
33 Vermeersch P, Van HL, Delforge M, et al. Diagnostic performance of serum free light chain measurement in patients suspected of a monoclonal B-cell disorder. British Journal of Haematology. Nov. 2008;143(4):496-502. [pmid: 18729849].
34 Dispenzieri A, Zhang L, Katzmann JA, et al. Appraisal of immunoglobulin free light chain as a marker of response. Blood. May. 15. 2008;111(10):4908-15. [pmid: 18364469].
35 Giarin MM, Giaccone L, Sorasio R, et al. Serum free light chain ratio, total kappa/lambda ratio, and immunofixation results are not prognostic factors after stem cell transplantation for newly diagnosed multiple myeloma. Clin Chem. Aug. 2009;55(8):1510-16. [pmid: 19520760].
36 Khoriaty R, Hussein MA, Faiman B, et al. Prediction of response and progression in multiple myeloma with serum free light chains assay: corroboration of the serum free light chain response definitions. Clinical lymphoma, myeloma & leukemia. Feb. 2010;10(1):E10-E13.
37 Kroger N, Asenova S, Gerritzen A, et al. Questionable role of free light chain assay ratio to determine stringent complete remission in multiple myeloma patients. Blood. 115(16):3413-14. [pmid: 20413663].
38 Kumar SK, Dispenzieri A, Lacy MQ, et al. Changes in serum-free light chain rather than intact monoclonal immunoglobulin levels predicts outcome following therapy in primary amyloidosis. American Journal of Hematology. Mar. 2011;86(3):251-55. [pmid: 21328431].
39 Kyrtsonis MC, Vassilakopoulos TP, Kafasi N, et al. Prognostic value of serum free light chain ratio at diagnosis in multiple myeloma. British Journal of Haematology. May. 2007;137(3):240-43. [pmid: 17408464].
40 Lachmann HJ, Gallimore R, Gillmore JD, et al. Outcome in systemic AL amyloidosis in relation to changes in concentration of circulating free immunoglobulin light chains following chemotherapy. British Journal of Haematology. Jul. 2003;122(1):78-84. [pmid: 12823348].
41 van RF, Bolejack V, Hollmig K, et al. High serum-free light chain levels and their rapid reduction in response to therapy define an aggressive multiple myeloma subtype with poor prognosis. Blood. Aug. 1. 2007;110(3):827-32. [pmid: 17416735].
42 Paiva B, Martinez-Lopez J, Vidriales MB, et al. Comparison of immunofixation, serum free light chain, and immunophenotyping for response evaluation and prognostication in multiple myeloma. Journal of Clinical Oncology. Apr. 20. 2011;29(12):1627-33. [pmid: 21402611].
43 Dytfeld D, Griffith KA, Friedman J, et al. Superior overall survival of patients with myeloma achieving very good partial response or better to initial treatment with bortezomib, pegylated liposomal doxorubicin, and dexamethasone, predicted after two cycles by a free light chain- and M-protein-based model: extended follow-up of a phase II trial. Leukemia & Lymphoma. Jul. 2011;52(7):1271-80. [pmid: 21699382].
44 Bladë J, Samson D, Reece D, et al. Criteria for evaluating disease response and progression in patients with multiple myeloma treated by high-dose therapy and haemopoietic stem cell transplantation. British Journal of Haematology. 1998;102(5):1115-23. [pmid: 9753033].
45 Greipp PR, Miguel JS, Durie BGM, et al. International Staging System for Multiple Myeloma. Journal of Clinical Oncology. May. 20. 2005;23(15):3412-20. [pmid: 15809451].
46 Durie BG, Salmon SE. A clinical staging system for multiple myeloma. Correlation of measured myeloma cell mass with presenting clinical features, response to treatment, and survival. Cancer. 1975;36:842-54. [pmid: 1182674].
47 Chee CE, Kumar S, Larson DR, et al. The importance of bone marrow examination in determining complete response to therapy in patients with multiple myeloma. Blood. Sep. 24. 2009;114(13):2617-18. [pmid: 19641191].
48 Kyle RA, Rajkumar SV. Criteria for diagnosis, staging, risk stratification and response assessment of multiple myeloma. Leukemia. 2009;23(1):3-9. [pmid: 18971951].
49 Palumbo A, Sezer O, Kyle R, et al. International Myeloma Working Group guidelines for the management of multiple myeloma patients ineligible for standard high-dose chemotherapy with autologous stem cell transplantation. Leukemia. Jun. 4. 2009;23(10):1716-30. [pmid: 19494840].
50 Abadie JM, van Hoeven KH, Wells JM. Are renal reference intervals required when screening for plasma cell disorders with serum free light chains and serum protein electrophoresis?. American Journal of Clinical Pathology. Feb. 2009;131(2):166-71. [pmid: 19141376].
51 Abraham RS, Katzmann JA, Clark RJ, et al. Quantitative analysis of serum free light chains. A new marker for the diagnostic evaluation of primary systemic amyloidosis. American Journal of Clinical Pathology. Feb. 2003;119(2):274-78. [pmid: 12579999].
52 Akar H, Seldin DC, Magnani B, et al. Quantitative serum free light chain assay in the diagnostic evaluation of AL amyloidosis. Amyloid. Dec. 2005;12(4):210-15. [pmid: 16399645].
53 Beetham R, Wassell J, Wallage MJ, et al. Can serum free light chains replace urine electrophoresis in the detection of monoclonal gammopathies?. Annals of Clinical Biochemistry. Nov. 2007;44(Pt:6):6-22.
54 Bochtler T, Hegenbart U, Heiss C, et al. Evaluation of the serum-free light chain test in untreated patients with AL amyloidosis. Haematologica. Mar. 2008;93(3):459-62. [pmid: 18287137].
55 Boer K, Deufel T. Quantitation of serum free light chains does not compensate for serum immunofixation only when screening for monoclonal gammopathies. Clinical Chemistry & Laboratory Medicine. 2009;47(9):1109-15. [pmid: 19728853].
56 Fulton RB, Fernando SL. Serum free light chain assay reduces the need for serum and urine immunofixation electrophoresis in the evaluation of monoclonal gammopathy. Annals of Clinical Biochemistry. Sep. 2009;46(Pt:5):5-12. [pmid: 19015220].
57 Hofmann W, Garbrecht M, Bradwell AR, et al. A new concept for detection of Bence Jones proteinuria in patients with monoclonal gammopathy. Clinical Laboratory. 2004;50(3-4):181-85. [pmid: 15074473].
58 Holding S, Spradbery D, Hoole R, et al. Use of serum free light chain analysis and urine protein electrophoresis for detection of monoclonal gammopathies. Clinical Chemistry & Laboratory Medicine. Jan. 2011;49(1):83-88. [pmid: 20961192].
59 Hutchison CA, Plant T, Drayson M, et al. Serum free light chain measurement aids the diagnosis of myeloma in patients with severe renal failure. BMC Nephrology. 2008;9:11. [pmid: 18808676].
60 Jaskowski TD, Litwin CM, Hill HR. Detection of kappa and lambda light chain monoclonal proteins in human serum: automated immunoassay versus immunofixation electrophoresis. Clinical & Vaccine Immunology: CVI. Feb. 2006;13(2):277-80. [pmid: 16467338].
61 Katzmann JA, Dispenzieri A, Kyle RA, et al. Elimination of the need for urine studies in the screening algorithm for monoclonal gammopathies by using serum immunofixation and free light chain assays. Mayo Clinic Proceedings. Dec. 2006;81(12):1575-78. [pmid: 17165636].
62 Katzmann JA, Kyle RA, Benson J, et al. Screening panels for detection of monoclonal gammopathies. Clin Chem. Aug. 2009;55(8):1517-22. [pmid: 19520758].
63 Marien G, Oris E, Bradwell AR, et al. Detection of monoclonal proteins in sera by capillary zone electrophoresis and free light chain measurements. Clin Chem. Sep. 2002;48(9):1600-01. [pmid: 12194945].
64 Nowrousian MR, Brandhorst D, Sammet C, et al. Serum free light chain analysis and urine immunofixation electrophoresis in patients with multiple myeloma. Clinical Cancer Research. Dec. 15. 2005;11(24:Pt 1):t-14.
65 Palladini G, Russo P, Bosoni T, et al. Identification of amyloidogenic light chains requires the combination of serum-free light chain assay with immunofixation of serum and urine. Clin Chem. Mar. 2009;55(3):499-504. [pmid: 19131635].
66 Ramasamy I. Serum free light chain analysis in B-cell dyscrasias. Annals of Clinical & Laboratory Science. 2007;37(3):291-94. [pmid: 17709698].
67 Sthaneshwar P, Nadarajan V, Maniam JA, et al. Serum free light chains: diagnostic and prognostic value in multiple myeloma. Clinical Chemistry & Laboratory Medicine. 2009;47(9):1101-07. [pmid: 19728852].
68 Wood PB, McElroy YG, Stone MJ. Comparison of serum immunofixation electrophoresis and free light chain assays in the detection of monoclonal gammopathies. Clinical lymphoma, myeloma & leukemia. Aug. 1. 2010;10(4):278-80.
69 Rajkumar SV, Kyle RA, Therneau TM, et al. Presence of monoclonal free light chains in the serum predicts risk of progression in monoclonal gammopathy of undetermined significance. British Journal of Haematology. Nov. 2004;127(3):308-10. [pmid: 15491291].
70 Cohen AD, Zhou P, Chou J, et al. Risk-adapted autologous stem cell transplantation with adjuvant dexamethasone +/- thalidomide for systemic light-chain amyloidosis: results of a phase II trial. British Journal of Haematology. Oct. 2007;139(2):224-33. [pmid: 17897298].
71 Hutchison CA, Bradwell AR, Cook M, et al. Treatment of acute renal failure secondary to multiple myeloma with chemotherapy and extended high cut-off hemodialysis. Clinical Journal of The American Society of Nephrology: CJASN. Apr. 2009;4(4):745-54. [pmid: 19339414].
72 Barlogie B, Alexanian R, Jagannath S. Plasma Cell Dyscrasias. JAMA: The Journal of the American Medical Association. Nov. 25. 1992;268(20):2946-51. [pmid: 1433713].
73 Weiss BM, Minter A, Abadie J, et al. Patterns of monoclonal immunoglobulins and serum free light chains are significantly different in black compared to white monoclonal gammopathy of undetermined significance (MGUS) patients. American Journal of Hematology. Jun. 2011;86(6):475-78. [pmid: 21544856].
74 te VH, Knop I, Stam P, et al. N Latex FLC - new monoclonal high-performance assays for the determination of free light chain kappa and lambda. Clinical Chemistry & Laboratory Medicine. Aug. 2011;49(8):1323-32. [pmid: 21663464].
75 Reitsma JB, Rutjes AWS, Whiting P, et al. Chapter 9: Assessing methodological quality. Deeks JJ, Bossuyt PM, Gastonis C, editors. Cochrane Handbook for Systematic Reviews of Diagnostic Test Accuracy (v.1.0.0). The Cochrane Collaboration. 2009:1-24.