# Glossary

Cast nephropathy (or “myeloma kidney”): Disorder in which monoclonal urinary immunoglobulin light chains (Bence Jones proteins) lead to acute or chronic renal failure through intratubular cast formation and direct tubular toxicity
Differential verification: Verification of test result or disease status of each patient using one of a variety of standards rather than one reference standard across the whole study population, which is problematic if the tests vary in accuracy (Reitsma 2009^75^)
Disease progression or recovery bias: Bias from an inappropriately long interval (or any interval) between conduct of reference test and conduct of index test (Reitsma 2009^75^)
Incorporation bias: Bias caused by use of a reference test consisting of a suite of investigations, including the index test results (and thereby overestimating the diagnostic accuracy of the index test) (Reitsma 2009^75^)
Involved FLC or SFLC: The free light chain or serum free light chain that is produced in excess and is causing disease (either kappa or lambda)
Light chain escape: A type of plasma-cell-dyscrasia remission in which, for unclear reasons, a subclone of malignant plasma cells expands that is incapable of producing significant amounts of immunoglobulin heavy chain but retains the ability to make light chains (Dispenzieri 2009^11^)
Measurable disease: Presence of a plasma cell dyscrasia but absence of elevated SFLC concentrations before treatment, therefore precluding use of the SFLC assay as a marker of disease and treatment response
M protein or paraprotein: Intact immunoglobulins or FLCs of a single type produced in excess by an abnormally expanded clone of malignant plasma cells (biomarkers of PCDs)
Monoclonal gammopathy: Disease class comprising PCDs as well as other conditions such as hematological disorders associated with a monoclonal band
Oligosecretory MM: MM in which very small amounts of M protein are produced by the malignant plasma cells
Polyclonal gammopathy: Disease similar to monoclonal gammopathy (or PCD) except that the clonal expansion occurs across various B-cell populations that produce more than one kind of immunoglobulin
Selection bias (also called partial verification bias, workup bias, or sequential ordering bias): Bias resulting from failure to verify the disease status or test result of all, or a random selection of, enrolled patients with the use of the reference standard (Reitsma 2009^75^)
SFLC ratio: The ratio of kappa chains to lambda chains, for which the normal range is 0.26–1.65 (Katzmann 2006^9^)
Spectrum bias or effect: Bias caused by use of sampling methods unlikely to capture a representative sample (for purposes of this review; term also can refer to bias from representation of inappropriate patient population) (Reitsma 2009^75^)
Verification bias: Incomplete verification of index test results