# Peer Reviewers

Adam D. Cohen, M.D.

Assistant Professor of Medical Oncology

Fox Chase Cancer Center

Philadelphia, PA

Rochelle Fu, Ph.D.

Associate Professor of Biostatistics

Oregon Evidence-based Practice Center

Department of Public Health and Preventive Medicine

Oregon Health and Science University

Portland, OR

Jerry Katzmann, Ph.D.

Associate Professor of Biochemistry & Molecular Biology and Laboratory Medicine

Mayo Clinic

Rochester, MN