# Technical Expert Panel

Laura M. Dember, M.D.

Professor of Medicine

Renal, Electrolyte and Hypertension Division

University of Pennsylvania Perelman School of Medicine

Philadelphia, PA

Shaji Kumar, M.D.

Associate Professor of Medicine at Mayo Clinic College of Medicine

Mayo Clinic

Rochester, MN

Martha Q. Lacy, M.D.

Professor of Medicine at Mayo Clinic College of Medicine

Mayo Clinic

Rochester, MN

Barbarajean Magnani, Ph.D., M.D.

Pathologist-in-Chief

Department of Pathology and Laboratory Medicine, Tufts Medical Center

Professor of Pathology, Tufts University School of Medicine

Boston, MA

Susan Miller Maynard, B.S., M.S., Ph.D., F.A.C.B.

Director of Chemistry and Toxicology

Carolinas Medical Center

Charlotte, NC

Philip McCarthy Jr., M.D.

Professor of Oncology

Director of Blood & Marrow Transplant Program

Roswell Park Cancer Institute

Buffalo, NY