# Key Informants

James Adamson, M.D.

Senior VP and Medical Officer for National Accounts

Arkansas Blue Cross Blue Shield

Little Rock, AR

Michael Katz

Vice President of International Myeloma Foundation

Los Angeles, CA

Susan Miller Maynard, B.S., M.S., Ph.D., F.A.C.B.

Director of Chemistry and Toxicology

Carolinas Medical Center

Charlotte, NC

Mary E. O'Donnell

President/CEO of Amyloidosis Foundation

Clarkston, MI

Mitchell G. Scott, Ph.D.

Professor of Pathology and Immunology

Co-Medical Director, Clinical Chemistry

Washington University School of Medicine

St. Louis, MO