# Discussion

Since its introduction in 2001, the SFLC assay has been used in various clinical contexts: screening and diagnosis of PCDs, baseline measurement of SFLCs for disease prognostication, and quantitative monitoring of patients treated for PCDs in order to document treatment response, disease remission, or relapse. In the present review, we assessed the comparative effectiveness of the SFLC assay as an adjunct to traditional tests such as SPEP and SIFE for the diagnosis of PCD in populations suspected of having the disease. We also ascertained the assay's ability, relative to traditional testing, to predict progression of MGUS to MM; its utility in prognostication for malignant PCDs; its role in determining treatment decisions; and whether its use could eliminate the need for other diagnostic tests. Table 11 summarizes the main findings addressing the five KQs of this CER.

Table 11 Summary of findings for KQs 1–5

KQ | Strength of Evidence | Summary, Comments, and Conclusions
KQ1: Do the SFLC assay and the SFLC ratio improve diagnostic accuracy for PCDs when combined with traditional tests, compared with traditional tests alone, in undiagnosed patients with suspected PCD? | Insufficient (favoring use of the SFLC assay and ratio) | Three retrospective studies (all quality B) directly evaluated the SFLC assay in the context of diagnosing PCDs. All 3 compared test results with the diagnosis of disease verified by medical records. Although these studies showed an increase in sensitivity with the addition of the SFLC assay, owing to the heterogeneity in design, patient selection, and comparators used, meta-analysis could not be performed. The effect on specificity was inconsistent. Conclusions: The SFLC assay appears to increase the sensitivity for diagnosis of PCD, although the effect on specificity was inconsistent. We rated the strength of evidence as insufficient, favoring the addition of the SFLC assay and ratio to the diagnostic test panel for PCDs.
KQ2: As compared with traditional tests, how well does the SFLC assay independently predict progression to MM in patients with MGUS? | Insufficient | No studies directly compared the use of the SFLC assay with traditional tests to determine whether it provided better prediction of progression to MM Conclusions: Owing to the lack of directly applicable data, we rated the evidence as insufficient.
KQ3: In patients with an existing diagnosis of PCD, does the use of the SFLC assay result in different treatment decisions with regard to timing, type, or duration of therapy as compared with traditional tests? | Insufficient | No studies directly compared the use of the SFLC assay with traditional tests to determine whether treatment decisions were different with regard to timing, duration, or type of treatment. Conclusions: Owing to the lack of directly applicable data, we rated the evidence as insufficient.
KQ4: In PCD patients, is the SFLC assay a better indicator of response to treatment, and of outcomes (overall survival, disease-free survival, remission, light chain escape, and quality of life) than traditional tests? | Insufficient for SFLC response as a better predictor of survival than M protein response in AL amyloidosis and in MM; also insufficient for other outcomes specified | One prospective study, 10 retrospective studies, and 1 study of unclear design (3 quality B, 8 quality C) evaluated the SFLC assay used in parallel with traditional tests in relationship to clinical outcomes, including survival. Three studies were in patients with AL amyloidosis and evaluated response to treatment as a predictor of outcomes; the other 8 studies were in patients with MM and evaluated either responses of SFLC or M protein to treatment or baseline levels of SFLC or M protein as predictors of clinical outcomes. The 3 retrospective studies in AL amyloidosis showed that patients with greater reductions in abnormal SFLC concentrations (a >50% or >90% reduction, vs. lesser reductions) after treatment (either chemotherapy or stem-cell transplantation) had better survival outcomes. The relationship between quantitative reduction in M protein and outcomes was inconsistent across studies. The prevalence of measurable disease limited the use of the SFLC assay, precluding its utility in patients without elevated levels before treatment. Five of the 8 studies that enrolled patients with MM addressed the use of SFLC assay in the assessment or prediction of treatment response. The traditional test comparators differed in each study. Four of the studies included patients who achieved an SFLC response earlier than a response by traditional tests; 2 examined the relationship between baseline SFLC concentrations and survival; 3 examined the relationship between post-treatment SFLC level and survival. Studies that addressed changes in SFLC or M protein relative to survival showed conflicting results. Conclusions: Although SFLC response to therapy appeared to be a consistent predictor of outcomes in AL amyloidosis, there was no evidence that the SFLC assay is superior to traditional tests, as direct comparisons were unavailable. Similarly, there was no evidence to ascertain whether SFLC response was a better predictor of outcomes than traditional tests in MM. We rated the strength of evidence as insufficient for the SFLC response as a better predictor of survival in AL amyloidosis and insufficient for the SFLC response as a better predictor of survival in MM.
KQ5: In PCD patients, does the use of the SFLC assay reduce the need for other diagnostic tests (e.g., bone marrow biopsy)? | Insufficient to support that use of the SFLC assay reduces the need for other diagnostic tests | One study (quality C) addressed this question. The study is a retrospective review of patients with a negative IFE test after treatment of MM who had a concomitant evaluable bone marrow aspiration or biopsy. A subset of patients also had data on the SFLC ratio; among those whose ratio normalized, the percentage of clonal plasma cells in the bone marrow was examined. A total of 14% of patients with a negative IFE test had ≥5% plasma cells in bone marrow, as did10% with a normal SFLC ratio. The authors recommended that, even if the SFLC assay is used, bone marrow examination should not be eliminated for the assessment of response.

AL amyloidosis=systemic amyloidosis in which amyloid [A] proteins derived from immunoglobulin light chains [L] are deposited in tissue, IFE=immunofixation electrophoresis, KQ=Key Question, MGUS=monoclonal gammopathy of undetermined significance, MM=multiple myeloma, PCD=plasma cell dyscrasia, SFLC=serum free light chain.

Our results reveal that there is a paucity of evidence to clarify the comparative effectiveness of the role of the SFLC assay for the diagnosis, management, and prognosis of PCDs. Only 15 studies were identified in our literature search, having met all the inclusion criteria to address the KQs and being comparative in nature (see Appendix B for the excluded studies). Many articles evaluating the effectiveness and role of the SFLC assay were excluded because the populations did not fit into the specified eligibility criteria or there was a lack of data for traditional testing as a comparator. Across the included studies, there was considerable clinical heterogeneity with regard to variation in type or stage of disease and phase of treatment. In addition, although in the 15 studies the SFLC assay and traditional testing were commonly conducted in parallel, they were not formally compared. That is, the studies did not include statistical comparisons of predictive value by comparing areas under a receiver-operating-characteristic curve or strength of association within models using measures such as likelihood ratios. The study heterogeneity observed with variations in study design and population, as well as inconsistency in the comparisons being made, may also reflect the uncertainties associated with the role of the assay in research and clinical practice. Finally, the majority of studies were of poor quality. All these factors limited the validity of the studies and the conclusions that could be drawn from them.

The role of the assay also remains uncertain in certain PCDs such as NSMM, LCMM, and AL amyloidosis, particularly in addressing comparative effectiveness. The insufficient evidence in these disease subgroups indicates areas needing targeted research in the future. We also found that much of the available research did not meet stringent reporting standards, and this finding should inform the conduct of future studies.

To synthesize our overall findings in more detail, below we present specific summaries of the state of the evidence for each KQ for which we found relevant publications (i.e., KQ1, KQ4, and KQ5) and describe the major needs of future studies.

## SFLC Assay and Diagnostic Testing (KQ1)

The addition of SFLC testing to traditional tests of electrophoresis and/or IFE for the diagnostic screening of patients suspected of having a PCD was evaluated in three studies, all quality B.31-33 The studies were all retrospective, conducted in a hospital laboratory setting, and were of adults suspected to have a monoclonal gammopathy. They used archived laboratory samples that had been obtained for SPEP or UPEP. All three studies reported that the addition of the SFLC assay to traditional tests increased diagnostic sensitivity although the effect on diagnostic specificity was inconsistent.

Several limitations and potential biases in these studies make it difficult to present clear conclusions regarding the comparative effectiveness of the SFLC assay and limit the studies' utility for informing clinical practice. We found that demographic details, including racial breakdown and comorbid conditions, were underreported. Quantitative synthesis across the studies was not possible because of variation in the methods used to select patients, the types of PCDs examined, the specific comparisons addressed, and whether patients with MGUS were included.

The presence of symptoms or laboratory abnormalities suggestive of a PCD usually triggers screening tests. Traditionally SPEP and UPEP would be performed; current recommendations include the SFLC assay as well.11 Positive tests would be followed with more detailed testing, including IFE and bone marrow examination.48,49 Ultimately, then, the diagnosis is based on a set of criteria including the results of the screening tests. There are potentially several types of biases that can affect diagnostic-test studies for PCDs that should be considered when interpreting the results. Incorporation bias is often difficult to eliminate because the result from the reference test itself (e.g., SPEP or SIFE) is usually considered along with other factors, such as clinical information, to reach a diagnosis of PCD. Selection bias could occur if study samples from large laboratory repositories are selected on the basis of the need to perform SPEP and the availability of parallel SFLC and traditional test results. Another important caveat is that the diagnostic performance of the SFLC assay varies depending on the type and distribution of PCDs in the study sample. The SFLC assay detects polyclonal, not monoclonal, light chains and is only useful for PCDs associated with light chain production.

A related source of bias in this context is spectrum bias, in which the reported sensitivity and specificity may be exaggerated in populations with increased disease severity. Some measures recommended to maximize the quality of test interpretation include repeat testing and targeted followup of false positives, as well as blinding of data assessors to the diagnosis or test group to diminish the likelihood of misclassification bias. However, such safeguards were seldom emphasized in the studies reviewed. The possibility of multiple samples from the same patient being analyzed without accounting for nonindependence was also not explicitly discussed. Few studies were designed a priori as studies of diagnostic-test performance with an adequately powered sampling scheme, and not all studies included evaluation of significance or precision in the form of hypothesis testing or estimation of confidence intervals.

Patients without a pre-existing diagnosis of PCD were selected as the relevant target population for KQ1, with input from the Technical Expert Panel. This approach was taken to allow for a comparison of test accuracy among patients that were not preselected as having disease. The purpose of this review was to examine the value added by SFLC testing to existing traditional tests; the population of interest was undiagnosed patients. Diagnostic studies using data only from patients already known to have PCDs were excluded from this CER (see Appendix B). We understand that studies of patients known to have PCDs have already been used to inform clinical practice. However, data from already diagnosed patients could potentially bias the evidence, as they reflect the extreme end of the spectrum of disease severity, where the proportion of patients with a positive test is overestimated. Moreover, without studying a nondiseased population, true negatives cannot be assessed. Certain study designs such as the case–control approach, with different enrollment strategies for the disease and control groups, could exaggerate the reported sensitivity and specificity, invoking the possibility of spectrum bias.

Although there is a large body of literature relating to the effectiveness of the SFLC assay in diagnosis of various PCDs, there is limited information on its comparative effectiveness. Most studies assessing comparative effectiveness have either compared the SFLC assay alone (not as an adjunct) versus one or more traditional tests, in either undiagnosed or diagnosed populations12,50-68 or have examined the SFLC assay as an adjunct but only in populations already diagnosed with a monoclonal gammopathy or AL amyloidosis. Several studies examined the issue of test accuracy in patients diagnosed with disease. These studies did not meet our population eligibility criterion, as they could not address test performance in patients who did not have disease. Included in these studies was one large trial: Katzmann 2009, that tested 1877 patients with a diagnosis of PCD by the SFLC assay, SPEP, UPEP, SIFE, or UIFE.62 The authors examined the diagnostic accuracy of these tests singly and in combination. Other studies compared the SFLC assay as a standalone test (not in combination with traditional testing) with traditional tests. Only two of these studies were carried out in undiagnosed patients, comparing SFLC testing alone with traditional testing, one for the detection of monoclonal protein (n=691)54 and one for the diagnosis of monoclonal gammopathy (n=753).55,58

## SFLC Assay and Treatment Response and Survival (KQ4)

Eleven studies, three in patients with AL amyloidosis13,38,40 and eight in patients with MM,34-37,39,41-43 evaluated SFLC testing compared with traditional testing for assessing treatment response and in relation to outcomes (overall survival, disease-free survival, remission, light chain escape, or quality of life). The studies varied in their inclusion criteria and treatments analyzed, as well as in the proportions of patients with newly diagnosed or relapsed disease and the types of traditional test used as a comparator for the SFLC assay.

The three studies of AL amyloidosis examined the relationship of SFLC response to treatment and outcomes, in addition to measuring quantitative M protein responses and independently evaluating the ability of each to predict outcomes. In all three, a reduction in the SFLC concentration after treatment was associated with improved survival. Despite this finding, it was not possible to determine whether SFLC testing is superior to traditional testing, since SFLC responses and M protein responses were not compared directly. All three studies were given a quality C grade, as they were small and retrospective with evidence of selection bias. The strength of evidence underlying this comparison was therefore rated as insufficient.

Eight studies were reviewed in patients with MM.34-37,39,41-43 Most (75 percent) were retrospective cohort studies, and only three were of quality B. Five addressed the use of SFLC assay in assessing or predicting response to treatment. The traditional test comparators reported varied in each study. Discordance of the SFLC response and the response as assessed by traditional testing was found in all the studies, but four reported achievement of an SFLC response prior to a response on traditional tests. Two studies examined the relationship between baseline SFLC concentrations and survival, and three examined the relationship between post-treatment SFLC level and survival. Studies that addressed changes in SFLC or M protein relative to survival showed conflicting results. The strength of evidence for SFLC response being a better predictor of survival than traditional testing was rated as insufficient. Consideration of the B quality studies only did not qualitatively change the pattern of observations outlined above or the grading of the strength of evidence. In the literature search, we found other studies of SFLC concentrations as a prognostic indicator in MM with regard to survival outcomes, renal outcomes, and light chain escape, but none were comparative in nature.

The strength of evidence for this KQ was insufficient for both AL amyloidosis and MM for all outcomes examined. Limitations in the literature reviewed were several. Demographic details, including distributions of races or ethnic groups and comorbid conditions, were not consistently reported. Information was limited regarding high-risk subgroups, such as patients with renal involvement, as well as patients across the disease spectrum (e.g., encompassing a range of types of PCD, or those without measurable disease versus those with only SFLC production). Also, many of the studies were conducted in either single centers or as ancillary studies to preexisting trials. All these issues limit the applicability of the findings to both the general PCD population and subgroups of interest.

## SFLC Assay in Outcome Prediction, Treatment Decisions, and Reducing Other Diagnostic Tests (KQ2, KQ3, and KQ5)

We did not find any studies comparing the SFLC assay with traditional tests in predicting progression of MGUS to MM (to address KQ2). The literature reviewed in relation to this KQ consisted of two retrospective cohort studies and one case–control study that compared rates of progression among patients with different baseline SFLC ratios but not in comparison to traditional testing.17,18,69 There is a growing awareness that patients with MGUS who have elevated SFLC concentrations may have a different disease biology than patients with MGUS whose SFLC concentrations are normal, and some incorporate the SFLC ratio into risk-scoring systems for MGUS progression.

No studies compared the use of the SFLC assay with traditional tests to determine whether treatment decisions changed (with regard to timing, duration, or type of treatment) to address KQ3. Two noncomparative studies reported results of treatment protocols determined by SFLC testing, one to define the need for adjuvant therapy in patients with AL amyloidosis70 and the other to determine the need for high-cut-off hemodialysis in combination with chemotherapy for the removal of SFLCs in patients with cast nephropathy.71 More information in this context is anticipated from the results of the BMT CTN 0702 trial (Center for International Blood and Marrow Transplant Research [www.cibmtr.org/Studies/ClinicalTrials/BMT_CTN/Protocols/Pages/0702.aspx]), which will be prospectively collecting serum samples for light chain analysis, along with flow-cytometry measurement of bone marrow and traditional tests for M protein. This should provide useful information regarding the role of the SFLC assay in monitoring MM patients.

A single study, Chee 2009,^47^ explored whether the use of the SFLC assay compared with traditional testing would reduce the need for other diagnostic tests (re KQ5). The authors evaluated whether a negative IFE result or normalization of the SFLC ratio (or both) after treatment of MM is sufficient to characterize a hematological response,22,27 such that the need for bone marrow examination to evaluate the percentages of plasma cells (to stringently define remission) could potentially be eliminated. Bone marrow examinations can be cumbersome in clinical practice and uncomfortable for patients, causing considerable noncompliance among physicians. Ten percent of patients with such an achievement still had 5 percent or more of plasma cells in marrow, and the authors concluded that bone marrow examination should not be eliminated for the assessment of treatment response. Since this conclusion is based on one study only, this question requires more detailed and systematic evaluation.

## Limitations

As discussed above, the present systematic review is subject to several important limitations. Few studies were available for specific comparisons between SFLC testing and traditional testing; the studies showed wide clinical heterogeneity stemming from the variation in the populations, interventions (diagnostic test/disease monitoring), and outcomes examined; and many were rated as poor quality. Comparators selected for the review were those that were in general use at the time of the review and do not include newer advances such as positron emission tomography. Finally, most studies were underpowered with respect to PCDs where the comparative role of the SFLC assay would have been the most meaningful, such as AL amyloidosis, LCMM, or NSMM.

## Applicability

MGUS and other PCDs are known to be more common in African-Americans than in Caucasians in the United States,72 but no studies that were included in our review addressed whether race modifies the applicability of the SFLC assay for diagnosis and monitoring of disease. African-American patients with MGUS have been found to have different laboratory findings than Caucasians, although the biologic differences underlying this and the effect on prognosis is unknown.73

We had to exclude the majority of studies of diagnostic accuracy of SFLC testing we found because they were carried out in populations with preexisting diagnosis of disease. These findings cannot readily be generalized to undiagnosed populations, which is the population of interest. Although such studies were excluded from our review, we found that the included studies also have potential biases (selection, spectrum, incorporation, and other types of bias) that limited generalizability.

Studies that addressed SFLC testing as a treatment marker for monitoring disease were often underpowered and failed to identify PCD subgroups as distinct risk categories. Given the biologic basis of the test, the comparative role of the SFLC assay is likely to be the most meaningful if disease expression is influenced by the function of a malignant clone of plasma cells that make light chains. Such a situation may apply to certain types of disease (e.g., AL amyloidosis, LCMM, or NSMM) or stages of disease (e.g., response to treatment, relapse, or light chain escape). There were no studies that specifically targeted these settings.

## Context of Findings

Current clinical uses of the SFLC assay in MM and related disorders focus on three main areas: the diagnostic, therapeutic, and monitoring approach to PCDs.7 Here, we discuss the applicability of the evidence for comparative effectiveness for current practice.

In the setting of diagnosis, the SFLC assay has been used primarily in patients suspected of having a PCD. The SFLC assay in combination with SPEP and SIFE is highly sensitive and its use potentially negates the need for 24-hour urine studies for diagnoses other than AL amyloidosis. In this CER, we identified only three studies that assessed the added value of the FLC assay in undiagnosed populations compared with traditional testing. Given the practical difficulties associated with obtaining a 24-hour urine sample, SFLC assay would be of tremendous value if its effectiveness is confirmed. Although the comparative diagnostic efficacy of the SFLC assay versus UPEP or UIFE has been shown in patients with preexisting disease, it has not yet been shown in undiagnosed populations, where the danger of false negatives for the SFLC assay has not been thoroughly vetted. On the other hand, if an abnormal SFLC ratio is the only test in a diagnostic panel that signals a PCD (e.g., light chain MGUS17), it will be difficult to further evaluate positive test results that may be erroneous. This conundrum exemplifies the challenges surrounding evaluation of a test in monoclonal disorders, given their heterogeneity and need for a multiplicity of tests to define a full diagnosis. It is likely that studies based on diagnostic samples from patients with confirmed disease will yield inflated estimates of test accuracy.

The baseline measurement of FLCs has been found to have major prognostic value for virtually every PCD. Another important group is the oligosecretory PCDs (including AL amyloidosis, NSMM, and LCMM), for which the SFLC assay can be useful for quantitative monitoring of patients. This assay has been used as a clinical tool in both settings. However, we found no evidence to assess its comparative value against traditional testing or bone marrow examination.

The SFLC kappa/lambda ratio has also been used to define a stringent complete treatment response.22 We did not find sufficient evidence that a complete response, defined with or without the SFLC ratio criteria, provided differential prognoses for progression-free survival or overall survival or that stringent complete response correlated with bone marrow response. The recognition of light chain escape by periodic SFLC measurements is another relevant indication for the use of the assay in therapeutic monitoring, given the changing disease behavior in response to chemotherapy. However, we found very few studies addressing light chain escape.

In summary, this CER demonstrates a paucity of evidence to determine the benefits of the use of SFLC assay instead of or as an adjunct to traditional testing. While the clinical effectiveness of the test in various settings was not the focus of the CER, its end users—clinicians, consumers, and policymakers—should be aware that there remains uncertainty regarding SFLC testing in a comparative context. There are clear evidence gaps for the clinician who is using the test, and these lend themselves to defining the particular research gaps that we focus on in the next section.

## Future Research

Uncertainties remain regarding the applications of the SFLC assay both within and beyond the 2009 IMWG consensus guidelines.11 Areas of uncertainty span the comparative effectiveness of the adjunctive role of the assay for the diagnosis of PCDs and the adjunctive and independent role of the assay in therapeutic decisions and monitoring, recognition of response and remission, and predicting clinical outcomes and prognosis among patients with diagnosed PCDs. The available data do not completely answer important clinical questions relevant to patient management; further research is needed to help elucidate these issues. However, given the widespread use and acceptance of SFLC testing in practice and clinical impression of its effectiveness, the role of future research into the assay's comparative effectiveness should be targeted toward populations and settings that will potentially maximize its utility.

### SFLC Assay in Diagnostic Testing

Prospectively designed single-cohort studies consisting of both diseased and nondiseased people, representative of the clinically relevant population where a PCD may be suspected, are needed to provide a more accurate assessment of the effect of adding SFLC to traditional tests used to diagnose PCDs. Studies should have a priori calculation of the sample size needed for determination of the desired precision and should include inferences based on formal statistical testing of estimates of diagnostic accuracy. Although it has been repeatedly suggested that serum SFLC measurement can replace the 24-hour urine collection for UPEP or UIFE in diagnostic panels, these studies have only been performed in patients with disease, so evidence for replacement is still lacking.

There are practical difficulties associated with obtaining a urine sample, and much of the SFLC assay's value is that it does not require urine collection. While the comparative diagnostic performance of the SFLC assay and UPEP or UIFE has been shown in patients with preexisting disease, this is not true of undiagnosed populations, where the danger of false negatives for the FLC assay has not been thoroughly vetted. More study is needed in this regard.

Inherent challenges exist in carrying out diagnostic-testing studies for PCDs, which should be addressed to facilitate further study. The potentially increased sensitivity of the SFLC assay has the downside of increasing the number of false positive results, but more systematic study of the false positive rate of the SFLC assay in different settings is needed, as is study of the best approach to resolve the discordance of a positive SFLC result but a negative result on traditional tests. Other important issues relate to validity of the published reference ranges, within-patient inconsistency in SFLC concentrations, and the harms of testing, questions that were outside the scope of this review. In addition, the lack of a suitable reference standard for PCD diagnosis and the need for a panel of tests to satisfy the criteria for diagnosis complicate the ability to make valid inferences from the data. Finally, conditions such as polyclonal gammopathy and diminished kidney function can produce false positive test results in the SFLC assay, and certain settings such as antigen excess and technical variations in commercial assays can produce false negative results.

As new diagnostic tests emerge for PCDs (e.g., positron emission tomography26) and modifications of the SFLC assay evolve (e.g., “N Latex” SFLC assay74), future research is needed to elucidate how these tests affect the clinical use of the SFLC assay.

### SFLC Assay in Risk Stratification and in Determining Prognosis

In addition to its diagnostic use, the SFLC assay is being used to monitor the course of PCDs characterized by light chain production (e.g., MM, NSMM, LCMM, AL amyloidosis, and light chain deposition disease). Definitions of FLC response are largely empirical in the current guidelines for AL amyloidosis (Consensus Opinion from the 10th International Symposium on Amyloid and Amyloidosis) and MM (International Uniform Response Criteria) and have not been validated. Research is needed to address the best definition of FLC response and the relationship of FLC response to hematological response and M protein response, progression-free survival, and overall survival. Similarly, a range of definitions have been used to describe the predictive clinical findings of the SFLC assays, including the absolute concentrations of the involved light chain, the difference between the concentrations of either each type of light chain, and the SFLC ratio. These definitions are not standardized and it remains unclear which is optimal in a variety of clinical situations.

Future studies should clarify whether SFLC measurement can replace the 24-hour UPEP or UIFE in disease monitoring and the potential of the SFLC assay to obviate invasive testing such as bone marrow aspiration or biopsy or radiation exposure from skeletal surveys. In addition, there is a need to examine the role of the SFLC assay in risk stratification across the spectrum of PCDs, from MGUS to MM and its variants and AL amyloidosis. There is a growing awareness that specific gene rearrangements are associated with FLC production across the spectrum of PCDs. Risk stratification according to findings on the SFLC assay may therefore provide a marker for the biological variability of the PCD. Such insight could provide guidance about the timing, duration, or type of treatment decisions used. This could be a major area for future research.

### Reporting on the SFLC Assay

Finally, there is a need to standardize the reporting of SFLC results for diagnostic test performance studies or of cohort studies in this area. At a minimum, studies should consistently report complete information on the mode of enrollment and on population characteristics, including demographic data. Future studies of SFLC testing should also report details on frequency and periodicity of measurements to account for within-patient variability.

## Conclusions

We did not find sufficient evidence to determine whether the addition of the SFLC assay to traditional testing would increase the diagnostic accuracy of PCD or whether it would help prognosticate the disease course. Its precise role and optimal use across the spectrum of PCDs and clinical settings still needs to be defined. Potential areas where its benefit may be seen are in diagnosis and prognosis, monitoring of therapy, and aiding treatment decisions. Future research should focus on standardization of patient inclusion criteria, testing of diagnostic and disease monitoring algorithms, and defining outcome and response definitions.