# Quality Criteria and Individual Study Grades

Table for Key Question 1

Author Year [PMID] | Prospective/Retrospective | Selection/spectrum bias | Case–control design | Consecutive patient selection | Lack of verification bias | Blinded index-test readers | Proper analysis if repeated sampling | Time interval between index and reference test reported | Statistical test used to quantify uncertainty | Quality Grade | Summary of grade rationale
Abadie 2006^1^ [16682511] | R | Y | N | Y | Y | N | Y | N | N | B | No measure of statistical uncertainty, no major biases, clear description of population
Piehler 2008^2^ [18801937] | P | Y | N | Y | Y | N | Y | N | N | B | No measure of statistical uncertainty, no major biases, consecutive recruitment
Vermeersch 2008^3^ [18729849] | R | Y | Y | Y | Y | ND | Y | N | N | B | No measure of statistical uncertainty, described sample, no major biases

Y= Yes, N = No, ND = not described, P = Prospective study design, R = Retrospective study design.

Types of bias are defined in Glossary and also described at the end of each row under “Summary of grade rationale.”

Criteria are derived from STARD (www.stard-statement.org) and STROBE (www.strobe-statement.org).

Table for Key Questions 4–5

Author Year [PMID] | Prospective/Retrospective | Outcomes clearly defined | Bias present | Confounders clearly defined/analyzed | Loss to follow up explained | Population clearly described | Data lost/not analyzed/missing | Inclusion/exclusion criteria defined | Quality grade | Summary of grade rationale
Key Question 4
Dispenzieri, 2008^4^ [18364469] | R | Y | Y | N | ND | Y | N | Y | B | Retrospective without adjustment
Dytfeld, 2011^5^[21699382] | P | Y | Y | N | ND | Y | N | Y | C | Small sample size, sample not uniformly treated
Giarin, 2009^6^ [19520760] | R | Y | Y | N | ND | Y | N | Y | B | Retrospective without adjustment
Khoriaty, 2010^7^ [20223721] | R | Y | Y | N | ND | Y | N | Y | C | Small sample size, retrospective without adjustment
Kroger, 2010^8^ [2043663] | ? | N | ? | N | ND | N | N | Y | C | Letter to the editor with limited information, small sample size, SFLC response definitions not described, few details about study design, limited data
Kumar 2011^9^ [21328431] | R | Y | Y | N | ND | Y | N | Y | C | Retrospective, extreme selection/spectrum bias
Kyrtsonis, 2007^10^ [17408464] | P | Y | Y | N | ND | N | N | Y | C | Limited information about patient recruitment and study design, small sample size
Lachmann 2003^11^ [12823348] | P | Y | Y | N | ND | Y | N | Y | C | Retrospective, selection/spectrum bias, sample not uniformly treated
Paiva, 2011^12^ [21402611] | R | Y | Y | N | ND | Y | N | Y | C | Retrospective without adjustment, potential selection bias because inclusion was based on availability of serum samples
Sanchorawala 2005^13^ [16044137] | R | Y | N | N | ND | Y | N | Y | C | Retrospective, small sample size
Van Rhee, 2007^14^ [17416735] | P | Y | ? | N | ND | Y | N | Y | B | Retrospective with adjustment
Key Question 5
Chee 2009^15^ [19641191] | R | n | ? | N | ND | N | N | Y | C | Small sample, selection/spectrum bias

Y= Yes, N = No, ND = not described, P = Prospective study design, R = Retrospective study design, ? = unclear.

Types of bias are defined in Glossary and also described at the end of each row under “Summary of grade rationale.”

Criteria are derived from STARD (www.stard-statement.org) and STROBE (www.strobe-statement.org).

## Appendix C References

1 Abadie JM, Bankson DD. Assessment of serum free light chain assays for plasma cell disorder screening in a Veterans Affairs population. Annals of Clinical & Laboratory Science. 2006;36(2):157-62. [pmid: 16682511].
2 Piehler AP, Gulbrandsen N, Kierulf P, et al. Quantitation of serum free light chains in combination with protein electrophoresis and clinical information for diagnosing multiple myeloma in a general hospital population. Clin Chem. Nov. 2008;54(11):1823-30. [pmid: 18801937].
3 Vermeersch P, Van HL, Delforge M, et al. Diagnostic performance of serum free light chain measurement in patients suspected of a monoclonal B-cell disorder. British Journal of Haematology. Nov. 2008;143(4):496-502. [pmid: 18729849].
4 Dispenzieri A, Zhang L, Katzmann JA, et al. Appraisal of immunoglobulin free light chain as a marker of response. Blood. May. 15. 2008;111(10):4908-15. [pmid: 18364469].
5 Dytfeld D, Griffith KA, Friedman J, et al. Superior overall survival of patients with myeloma achieving very good partial response or better to initial treatment with bortezomib, pegylated liposomal doxorubicin, and dexamethasone, predicted after two cycles by a free light chain- and M-protein-based model: extended follow-up of a phase II trial. Leukemia & Lymphoma. Jul. 2011;52(7):1271-80. [pmid: 21699382].
6 Giarin MM, Giaccone L, Sorasio R, et al. Serum free light chain ratio, total kappa/lambda ratio, and immunofixation results are not prognostic factors after stem cell transplantation for newly diagnosed multiple myeloma. Clin Chem. Aug. 2009;55(8):1510-16. [pmid: 19520760].
7 Khoriaty R, Hussein MA, Faiman B, et al. Prediction of response and progression in multiple myeloma with serum free light chains assay: corroboration of the serum free light chain response definitions. Clinical lymphoma, myeloma & leukemia. Feb. 2010;10(1):E10-E13.
8 Kroger N, Asenova S, Gerritzen A, et al. Questionable role of free light chain assay ratio to determine stringent complete remission in multiple myeloma patients. Blood. 115(16):3413-14. [pmid: 20413663].
9 Kumar SK, Dispenzieri A, Lacy MQ, et al. Changes in serum-free light chain rather than intact monoclonal immunoglobulin levels predicts outcome following therapy in primary amyloidosis. American Journal of Hematology. Mar. 2011;86(3):251-55. [pmid: 21328431].
10 Kyrtsonis MC, Vassilakopoulos TP, Kafasi N, et al. Prognostic value of serum free light chain ratio at diagnosis in multiple myeloma. British Journal of Haematology. May. 2007;137(3):240-43. [pmid: 17408464].
11 Lachmann HJ, Gallimore R, Gillmore JD, et al. Outcome in systemic AL amyloidosis in relation to changes in concentration of circulating free immunoglobulin light chains following chemotherapy. British Journal of Haematology. Jul. 2003;122(1):78-84. [pmid: 12823348].
12 Paiva B, Martinez-Lopez J, Vidriales MB, et al. Comparison of immunofixation, serum free light chain, and immunophenotyping for response evaluation and prognostication in multiple myeloma. Journal of Clinical Oncology. Apr. 20. 2011;29(12):1627-33. [pmid: 21402611].
13 Sanchorawala V, Seldin DC, Magnani B, et al. Serum free light-chain responses after high-dose intravenous melphalan and autologous stem cell transplantation for AL (primary) amyloidosis. Bone Marrow Transplantation. Oct. 2005;36(7):597-600. [pmid: 16044137].
14 van RF, Bolejack V, Hollmig K, et al. High serum-free light chain levels and their rapid reduction in response to therapy define an aggressive multiple myeloma subtype with poor prognosis. Blood. Aug. 1. 2007;110(3):827-32. [pmid: 17416735].
15 Chee CE, Kumar S, Larson DR, et al. The importance of bone marrow examination in determining complete response to therapy in patients with multiple myeloma. Blood. Sep. 24. 2009;114(13):2617-18. [pmid: 19641191].