# Excluded Studies

Of the 325 articles obtained for full-text review, 15 were included and 310 were excluded; most failed to meet KQ inclusion criteria regarding the test, population, diagnosis, or comparison of interest. The other main reasons for exclusion were that the article was a narrative review, commentary, or letter without sufficient data or that it described a single case series.

All 310 excluded references are presented below, in alphabetic order of first author's surname, along with the reason for exclusion for each.

## Studies Excluded after Full-Text Review (n=310)

1 Abadie JM, van Hoeven KH, Wells JM. Are renal reference intervals required when screening for plasma cell disorders with serum free light chains and serum protein electrophoresis?. American Journal of Clinical Pathology. Feb. 2009;131(2):166-71. [pmid: 19141376]. Not relevant re test, population, diagnosis, or comparison
2 Abraham RS, Katzmann JA, Clark RJ, et al. Quantitative analysis of serum free light chains. A new marker for the diagnostic evaluation of primary systemic amyloidosis. American Journal of Clinical Pathology. Feb. 2003;119(2):274-78. [pmid: 12579999]. Not relevant re test, population, diagnosis, or comparison
3 Adamczyk M, Gebler JC, Wu J. Profiling of polyclonal antibody light chains by liquid chromatography/electrospray ionization mass spectrometry. Rapid Communications in Mass Spectrometry. 2000;14(1):49-51. [pmid: 10623928]. Not relevant re test, population, diagnosis, or comparison
4 Akar H, Seldin DC, Magnani B, et al. Quantitative serum free light chain assay in the diagnostic evaluation of AL amyloidosis. Amyloid. Dec. 2005;12(4):210-15. [pmid: 16399645]. Not relevant re test, population, diagnosis, or comparison
5 Alpay N, Artim-Esen B, Kamali S, et al. Amyloid arthropathy mimicking seronegative rheumatoid arthritis in multiple myeloma: case reports and review of the literature. Amyloid. Dec. 2009;16(4):226-31. [pmid: 19922335]. Not relevant re test, population, diagnosis, or comparison
6 Alyanakian MA, Abbas A, Delarue R, et al. Free immunoglobulin light-chain serum levels in the follow-up of patients with monoclonal gammopathies: correlation with 24-hr urinary light-chain excretion. American Journal of Hematology. Apr. 2004;75(4):246-48. [pmid: 15054820]. Not relevant re test, population, diagnosis, or comparison
7 Amersdorfer P, Marks JD. Phage libraries for generation of anti-botulinum scFv antibodies. Methods in Molecular Biology. 2000;145:219-40. [pmid: 10820725]. Not relevant re test, population, diagnosis, or comparison
8 Anagnostopoulos A, Galani E, Gika D, et al. Monoclonal gammopathy of undetermined significance (MGUS) in patients with solid tumors: effects of chemotherapy on the monoclonal protein. Annals of Hematology. Oct. 2004;83(10):658-60. [pmid: 15278296]. Not relevant re test, population, diagnosis, or comparison
9 Anagnostopoulos A, Hamilos G, Zorzou MP, et al. Discordant response or progression in patients with myeloma treated with thalidomide-based regimens. Leukemia & Lymphoma. Jan. 2004;45(1):113-16. [pmid: 15061206]. Not relevant re test, population, diagnosis, or comparison
10 Anand M, Singh S, Kumar R, et al. Value of immunofixation on serum in light-chain myeloma. Annals of Clinical Biochemistry. Nov. 2004;41(Pt:6):6-2. Not relevant re test, population, diagnosis, or comparison
11 Ansari NA, Owais M, Usha. Immunoglobulin heavy and light chain isotypes in multiple myeloma patients. Asian Pacific Journal of Cancer Prevention: Apjcp. Oct. 2007;8(4):593-96. [pmid: 18260735]. Not relevant re test, population, diagnosis, or comparison
12 Artero S, Lefranc MP. The telostei immunoglobulin light IGL1 and IGL2 V, J and C genes. Experimental & Clinical Immunogenetics. 2000;17(3):162-72. [pmid: 10899741]. Not relevant re test, population, diagnosis, or comparison
13 Attaelmannan M, Levinson SS. Understanding and identifying monoclonal gammopathies. [Review] [58 refs]. Clin Chem. Aug. 2000;46(8:Pt 2):t-8. Narrative review or commentary
14 Ayliffe MJ, Davies FE, de CD, et al. Demonstration of changes in plasma cell subsets in multiple myeloma. Haematologica. Aug. 2007;92(8):1135-38. [pmid: 17650446]. Not relevant re test, population, diagnosis, or comparison
15 Bakker AJ, Bierma-Ram A, Elderman-van der WC, et al. Quantitation of serum free light chains. Clin Chem. 2009;55(8):1585-87. [pmid: 19498053]. Letter without data
16 Bakshi NA, Gulbranson R, Garstka D, et al. Serum free light chain (FLC) measurement can aid capillary zone electrophoresis in detecting subtle FLC-producing M proteins. American Journal of Clinical Pathology. Aug. 2005;124(2):214-18. [pmid: 16040291]. Not relevant re test, population, diagnosis, or comparison
17 Barraclough KA, Dowling JP, Schwarer AP, et al. Sequential autologous peripheral blood stem cell transplantation and kidney transplantaion of light chain deposition disease. Nephrology Dialysis Transplantation. Apr. 2007;22(4):1268-69. Study of single case series
18 Bartels H, Dikkers FG, van der Wal JE, et al. Laryngeal amyloidosis: localized versus systemic disease and update on diagnosis and therapy. Annals of Otology, Rhinology & Laryngology. Sep. 2004;113(9):741-48. Not relevant re test, population, diagnosis, or comparison
19 Bayer-Garner IB, Prieto VG, Smoller BR. Detection of clonality with kappa and lambda immunohistochemical analysis in cutaneous plasmacytomas. Archives of Pathology & Laboratory Medicine. Jun. 2004;128(6):645-48. [pmid: 15163236]. Not relevant re test, population, diagnosis, or comparison
20 Beers R, Chowdhury P, Bigner D, et al. Immunotoxins with increased activity against epidermal growth factor receptor vIII-expressing cells produced by antibody phage display. Clinical Cancer Research. Jul. 2000;6(7):2835-43. [pmid: 10914732]. Not relevant re test, population, diagnosis, or comparison
21 Beetham R. Detection of Bence-Jones protein in practice. [Review] [53 refs]. Annals of Clinical Biochemistry. Sep. 2000;37(Pt 5):563-70. [pmid: 11026510]. Narrative review or commentary
22 Beetham R, Wassell J, Wallage MJ, et al. Can serum free light chains replace urine electrophoresis in the detection of monoclonal gammopathies?. Annals of Clinical Biochemistry. Nov. 2007;44(Pt:6):6-22. Not relevant re test, population, diagnosis, or comparison
23 Bergon E, Miravalles E, Bergon E, et al. The predictive power of serum kappa/lambda ratios for discrimination between monoclonal gammopathy of undetermined significance and multiple myeloma. [Erratum appears in Clin Chem Lab Med. 2005;43(3):349]. Clinical Chemistry & Laboratory Medicine. 2005;43(1):32-37. [pmid: 15653439]. Not relevant re test, population, diagnosis, or comparison
24 Bergon E, Miravalles E. Estimation of serum M-protein concentration from polyclonal immunoglobulins: an alternative to serum protein electrophoresis and standard immunochemical procedures. Clinical Chemistry & Laboratory Medicine. 2008;46(8):1156-62. [pmid: 18605957]. Not relevant re test, population, diagnosis, or comparison
25 Blade J. Clinical practice. Monoclonal gammopathy of undetermined significance. [Review] [31 refs]. New England Journal of Medicine. Dec. 28. 2006;355(26):2765-70. [pmid: 17192542]. Study of single case series
26 Blade J, Rosinol L, Cibeira MT, et al. Pathogenesis and progression of monoclonal gammopathy of undetermined significance. [Review] [63 refs]. Leukemia. Sep. 2008;22(9):1651-57. [pmid: 18668131]. Narrative review or commentary
27 Bochtler T, Hegenbart U, Heiss C, et al. Evaluation of the serum-free light chain test in untreated patients with AL amyloidosis. Haematologica. Mar. 2008;93(3):459-62. [pmid: 18287137]. Not relevant re test, population, diagnosis, or comparison
28 Boer K, Deufel T. Quantitation of serum free light chains does not compensate for serum immunofixation only when screening for monoclonal gammopathies. Clinical Chemistry & Laboratory Medicine. 2009;47(9):1109-15. [pmid: 19728853]. Not relevant re test, population, diagnosis, or comparison
29 Bosmann M, Kossler J, Stolz H, et al. Detection of serum free light chains: the problem with antigen excess. Clinical Chemistry & Laboratory Medicine. Oct. 2010;48(10):1419-22. [pmid: 20626301]. Not relevant re test, population, diagnosis, or comparison
30 Bradwell AR, Carr-Smith HD, Mead GP, et al. Highly sensitive, automated immunoassay for immunoglobulin free light chains in serum and urine. Clin Chem. Apr. 2001;47(4):673-80. [pmid: 11274017]. Not relevant re test, population, diagnosis, or comparison
31 Bradwell AR, Carr-Smith HD, Mead GP, et al. Serum test for assessment of patients with Bence Jones myeloma. Lancet. Feb. 8. 2003;361(9356):489-91. [pmid: 12583950]. Not relevant re test, population, diagnosis, or comparison
32 Briand PY, Decaux O, Caillon H, et al. Analytical performance of the serum free light chain assay. Clinical Chemistry & Laboratory Medicine. 2010;48(1):73-79. [pmid: 19929752]. Not relevant re test, population, diagnosis, or comparison
33 Brunvand MW, Bitter M. Amyloidosis relapsing after autologous stem cell transplantation treated with bortezomib: normalization of detectable serum-free light chains and reversal of tissue damage with improved suitability for transplant. Haematologica. Mar. 2010;95(3):519-21. [pmid: 19903681]. Not relevant re test, population, diagnosis, or comparison
34 Bui AT, Rosen BS, Roe RH, et al. Diagnostic and therapeutic challenges. Retina. Nov. 2010;30(10):1744-48. [pmid: 20683382]. Not relevant re test, population, diagnosis, or comparison
35 Burnette BL, Leung N, Rajkumar SV. Renal improvement in myeloma with bortezomib plus plasma exchange. New England Journal of Medicine. Jun. 16. 2011;364(24):2365-66. [pmid: 21675906]. Letter without data
36 Buxbaum JN. Abnormal immunoglobulin synthesis in monoclonal immunoglobulin light chain and light and heavy chain deposition disease. Amyloid. Jun. 2001;8(2):84-93. [pmid: 11409038]. Not relevant re test, population, diagnosis, or comparison
37 Cacoub P, Camproux AC, Thiolieres JM, et al. A new approach for rapid detection and typing of serum monoclonal components. Clinica Chimica Acta. Dec. 2000;302(1-2):105-24. Not relevant re test, population, diagnosis, or comparison
38 Carpenter GH, Proctor GB. Double electrophoretic separation and lectin analyses of the component chains of secretory immunoglobulin A from human saliva. Electrophoresis. May. 2000;21(8):1446-53. [pmid: 10832871]. Not relevant re test, population, diagnosis, or comparison
39 Charlton KA, Moyle S, Porter AJ, et al. Analysis of the diversity of a sheep antibody repertoire as revealed from a bacteriophage display library. Journal of Immunology. Jun. 15. 2000;164(12):6221-29. Not relevant re test, population, diagnosis, or comparison
40 Cherry SR, Beard C, Jaenisch R, et al. V(D)J recombination is not activated by demethylation of the kappa locus. Proceedings of the National Academy of Sciences of the United States of America. Jul. 18. 2000;97(15):8467-72. [pmid: 10880575]. Not relevant re test, population, diagnosis, or comparison
41 Ching AK, Li PS, Chan WY, et al. Strand bias in Ig somatic hypermutation is determined by signal sequence within the variable region. International Immunology. Sep. 2000;12(9):1245-53. [pmid: 10967019]. Not relevant re test, population, diagnosis, or comparison
42 Chiu YW, Chen R, Li QX, et al. Derivation and properties of recombinant Fab antibodies to coplanar polychlorinated biphenyls. Journal of Agricultural & Food Chemistry. Jun. 2000;48(6):2614-24. [pmid: 10888593]. Not relevant re test, population, diagnosis, or comparison
43 Cockwell P, Hutchison CA. Management options for cast nephropathy in multiple myeloma. [Review]. Current Opinion in Nephrology & Hypertension. Nov. 2010;19(6):550-55. [pmid: 20827195]. Narrative review or commentary
44 Cohen AD, Zhou P, Chou J, et al. Risk-adapted autologous stem cell transplantation with adjuvant dexamethasone +/- thalidomide for systemic light-chain amyloidosis: results of a phase II trial. British Journal of Haematology. Oct. 2007;139(2):224-33. [pmid: 17897298]. Not relevant re test, population, diagnosis, or comparison
45 Cohen AD, Comenzo RL. Systemic light-chain amyloidosis: advances in diagnosis, prognosis, and therapy. Hematology. 2010;2010:287-94. [pmid: 21239808]. Narrative review or commentary
46 Colombat M, Mal H, Copie-Bergman C, et al. Primary cystic lung light chain deposition disease: a clinicopathologic entity derived from unmutated B cells with a stereotyped IGHV4-34/IGKV1 receptor. Blood. Sep. 1. 2008;112(5):2004-12. [pmid: 18483396]. Not relevant re test, population, diagnosis, or comparison
47 Condon C, Hourihane SL, ng-Lawson M, et al. Aberrant trafficking of the B cell receptor Ig-alpha beta subunit in a B lymphoma cell line. Journal of Immunology. Aug. 1. 2000;165(3):1427-37. Not relevant re test, population, diagnosis, or comparison
48 Daval S, Tridon A, Mazeron N, et al. Risk of antigen excess in serum free light chain measurements. Clin Chem. Nov. 2007;53(11):1985-86. [pmid: 17954504]. Study of single case series
49 Davern S, Tang LX, Williams TK, et al. Immunodiagnostic capabilities of anti-free immunoglobulin light chain monoclonal antibodies. American Journal of Clinical Pathology. Nov. 2008;130(5):702-11. [pmid: 18854262]. Not relevant re test, population, diagnosis, or comparison
50 Davids MS, Murali MR, Kuter DJ. Serum free light chain analysis. [Review]. American Journal of Hematology. Oct. 2010;85(10):787-90. [pmid: 20721885]. Narrative review or commentary
51 de Kat Angelino CM, Raymakers R, Teunesen MA, et al. Overestimation of serum kappa free light chain concentration by immunonephelometry. Clin Chem. Jul. 2010;56(7):1188-90. [pmid: 20413429]. Not relevant re test, population, diagnosis, or comparison
52 de Larrea CF, Cibeira MT, Elena M, et al. Abnormal serum free light chain ratio in patients with multiple myeloma in complete remission has strong association with the presence of oligoclonal bands: implications for stringent complete remission definition. Blood. Dec. 3. 2009;114(24):4954-56. [pmid: 19797521]. Not relevant re test, population, diagnosis, or comparison
53 Dember LM. Light chains, casts, sheets and fibrils: monoclonal immunoglobulin diseases and immunotactoid/fibrillary glomerulopathy. Clinical Journal of The American Society of Nephrology: CJASN. Nov. 2006;1(6):1320-21. [pmid: 17699364]. Narrative review or commentary
54 Diamantidis MD, Ioannidou-Papagiannaki E, Ntaios G. Novel extended reference range for serum kappa/lambda free light chain ratio in diagnosing monoclonal gammopathies in renal insufficient patients. Clinical Biochemistry. Jul. 2009;42(10-11):1202-03. [pmid: 19375413]. Letter without data
55 Dietrich S, Schonland SO, Benner A, et al. Treatment with intravenous melphalan and dexamethasone is not able to overcome the poor prognosis of patients with newly diagnosed systemic light chain amyloidosis and severe cardiac involvement. Blood. Jul. 29. 2010;116(4):522-28. [pmid: 20375312]. Not relevant re test, population, diagnosis, or comparison
56 Dimopoulos M, Kastritis E. High dose therapy for light chain amyloidosis: can we reduce treatment related mortality further?. Leukemia & Lymphoma. Jan. 2008;49(1):4-5. [pmid: 18203000]. Narrative review or commentary
57 Dimopoulos M, Kyle R, Fermand JP, et al. Consensus recommendations for standard investigative workup: report of the International Myeloma Workshop Consensus Panel 3. Blood. May. 5. 2011;117(18):4701-05. [pmid: 21292778]. Not relevant re test, population, diagnosis, or comparison
58 Dingli D, Kyle RA, Rajkumar SV, et al. Immunoglobulin free light chains and solitary plasmacytoma of bone. Blood. Sep. 15. 2006;108(6):1979-83. [pmid: 16741249]. Not relevant re test, population, diagnosis, or comparison
59 Dispenzieri A, Lacy MQ, Katzmann JA, et al. Absolute values of immunoglobulin free light chains are prognostic in patients with primary systemic amyloidosis undergoing peripheral blood stem cell transplantation. Blood. Apr. 15. 2006;107(8):3378-83. [pmid: 16397135]. Not relevant re test, population, diagnosis, or comparison
60 Dispenzieri A, Kyle RA, Katzmann JA, et al. Immunoglobulin free light chain ratio is an independent risk factor for progression of smoldering (asymptomatic) multiple myeloma. Blood. Jan. 15. 2008;111(2):785-89. [pmid: 17942755]. Not relevant re test, population, diagnosis, or comparison
61 Dispenzieri A. Is early, deep free light chain response really an adverse prognostic factor?. Blood. 2008;111(4):2490-91. [pmid: 18263791]. Letter without data
62 Dispenzieri A, Kyle R, Merlini G, et al. International Myeloma Working Group guidelines for serum-free light chain analysis in multiple myeloma and related disorders. Leukemia. Feb. 2009;23(2):215-24. [pmid: 19020545]. Not relevant re test, population, diagnosis, or comparison
63 Dispenzieri A, Katzmann JA, Kyle RA, et al. Prevalence and risk of progression of light-chain monoclonal gammopathy of undetermined significance: a retrospective population-based cohort study. [Erratum appears in Lancet. 2010 Jul 31;376(9738):332]. Lancet. May. 15. 2010;375(9727):1721-28. [pmid: 20472173]. Not relevant re test, population, diagnosis, or comparison
64 Dogaru M, Lazar V, Coriu D. Assessing the efficiency of free light chain assay in monitoring patients with multiple myeloma before and after autologous stem cell transplantation along with serum protein electrophoresis and serum protein immunofixation. Romanian Archives of Microbiology & Immunology. Jan. 2011;70(1):15-22. [pmid: 21717807]. Study of a single case
65 Dong X, An B, Salvucci KL, et al. Modification of the amino terminus of a class II epitope confers resistance to degradation by CD13 on dendritic cells and enhances presentation to T cells. Journal of Immunology. Jan. 1. 2000;164(1):129-35. Not relevant re test, population, diagnosis, or comparison
66 Doyle A, Soutar R, Geddes CC. Multiple myeloma in chronic kidney disease. Utility of discretionary screening using serum electrophoresis. Nephron. 2009;111(1):c7-11. [pmid: 19033691]. Not relevant re test, population, diagnosis, or comparison
67 Doyle ML, Brigham-Burke M, Blackburn MN, et al. Measurement of protein interaction bioenergetics: application to structural variants of anti-sCD4 antibody. Methods in Enzymology. 2000;323:207-30. [pmid: 10944754]. Not relevant re test, population, diagnosis, or comparison
68 Drayson M, Tang LX, Drew R, et al. Serum free light-chain measurements for identifying and monitoring patients with nonsecretory multiple myeloma. Blood. May. 1. 2001;97(9):2900-02. [pmid: 11313287]. Not relevant re test, population, diagnosis, or comparison
69 Drayson M, Begum G, Basu S, et al. Effects of paraprotein heavy and light chain types and free light chain load on survival in myeloma: an analysis of patients receiving conventional-dose chemotherapy in Medical Research Council UK multiple myeloma trials. Blood. Sep. 15. 2006;108(6):2013-19. [pmid: 16728700]. Not relevant re test, population, diagnosis, or comparison
70 Elliott BM, Peti S, Osman K, et al. Combining FDG-PET/CT with laboratory data yields superior results for prediction of relapse in multiple myeloma. European Journal of Haematology. Apr. 2011;86(4):289-98. [pmid: 21198866]. Not relevant re test, population, diagnosis, or comparison
71 Feeney AJ. New alleles of human immunoglobulin kappa J segments IGKJ2 and IGKJ4. Immunogenetics. May. 2000;51(6):487-88. [pmid: 10866115]. Not relevant re test, population, diagnosis, or comparison
72 Feld JJ, Guindi M, Heathcote EJ. The lighter side of myeloma: an easily overlooked diagnosis. Gut. 2005;54(10):1376. [pmid: 16162950]. Not relevant re test, population, diagnosis, or comparison
73 Forsyth J, Hill P. Serum free light chains. Annals of Clinical Biochemistry. 2008;45(Pt:4):4-5. Letter without data
74 Fulton RB, Fernando SL. Serum free light chain assay reduces the need for serum and urine immunofixation electrophoresis in the evaluation of monoclonal gammopathy. Annals of Clinical Biochemistry. Sep. 2009;46(Pt:5):5-12. [pmid: 19015220]. Not relevant re test, population, diagnosis, or comparison
75 Gamba G, Montani N, Anesi E, et al. Clotting alterations in primary systemic amyloidosis. Haematologica. Mar. 2000;85(3):289-92. [pmid: 10702818]. Not relevant re test, population, diagnosis, or comparison
76 Gavrilov V, Yermiahu T, Gorodischer R. Urinary excretion of retinol in patients with multiple myeloma: a preliminary study. American Journal of Hematology. Nov. 2003;74(3):202-04. [pmid: 14587052]. Not relevant re test, population, diagnosis, or comparison
77 Gertz MA, Kyle RA. Amyloidosis with IgM monoclonal gammopathies. Seminars in Oncology. Apr. 2003;30(2):325-28. [pmid: 12720162]. Not relevant re test, population, diagnosis, or comparison
78 Gertz MA, Blood E, Vesole DH, et al. A multicenter phase 2 trial of stem cell transplantation for immunoglobulin light-chain amyloidosis (E4A97): an Eastern Cooperative Oncology Group Study. Bone Marrow Transplantation. Jul. 2004;34(2):149-54. [pmid: 15156165]. Not relevant re test, population, diagnosis, or comparison
79 Gertz MA, Lacy MQ, Dispenzieri A, et al. Amyloidosis: diagnosis and management. [Review] [103 refs]. Clinical Lymphoma & Myeloma. Nov. 2005;6(3):208-19. [pmid: 16354326]. Narrative review or commentary
80 Gertz MA, Leung N, Lacy MQ, et al. Clinical outcome of immunoglobulin light chain amyloidosis affecting the kidney. Nephrology Dialysis Transplantation. Oct. 2009;24(10):3132-37. Not relevant re test, population, diagnosis, or comparison
81 Gertz MA, Lacy MQ, Dispenzieri A, et al. Autologous stem cell transplant for immunoglobulin light chain amyloidosis: a status report. Leukemia & Lymphoma. Dec. 2010;51(12):2181-87. [pmid: 20958232]. Not relevant re test, population, diagnosis, or comparison
82 Gertz MA. Immunoglobulin light chain amyloidosis: 2011 update on diagnosis, risk-stratification, and management. American Journal of Hematology. Feb. 2011;86(2):180-86. [pmid: 21264900]. Not relevant re test, population, diagnosis, or comparison
83 Gertz MA, Buadi FK, Hayman SR. IgM amyloidosis: clinical features in therapeutic outcomes. [Review]. Clinical lymphoma, myeloma & leukemia. Feb. 2011;11(1):146-48. Not relevant re test, population, diagnosis, or comparison
84 Gokden N, Cetin N, Colakoglu N, et al. Morphologic manifestations of combined light-chain deposition disease and light-chain cast nephropathy. Ultrastructural Pathology. Mar. 2007;31(2):141-49. [pmid: 17613994]. Not relevant re test, population, diagnosis, or comparison
85 Graziani MS, Merlini G. Measurement of free light chains in urine. Clin Chem. Nov. 2001;47(11):2069-70. [pmid: 11673389]. Letter without data
86 Guo B, Kato RM, Garcia-Lloret M, et al. Engagement of the human pre-B cell receptor generates a lipid raft-dependent calcium signaling complex. Immunity. Aug. 2000;13(2):243-53. [pmid: 10981967]. Not relevant re test, population, diagnosis, or comparison
87 Hanson BL, Bunick GJ, Harp JM, et al. Mcg in 2030: new techniques for atomic position determination of immune complexes. [Review] [29 refs]. Journal of Molecular Recognition. Sep. 2002;15(5):297-305. [pmid: 12447907]. Not relevant re test, population, diagnosis, or comparison
88 Harding SJ, Mead GP, Bradwell AR, et al. Serum free light chain immunoassay as an adjunct to serum protein electrophoresis and immunofixation electrophoresis in the detection of multiple myeloma and other B-cell malignancies. Clinical Chemistry & Laboratory Medicine. 2009;47(3):302-04. [pmid: 19676141]. Not relevant re test, population, diagnosis, or comparison
89 Harris DL, King E, Ramsland PA, et al. Binding of nascent collagen by amyloidogenic light chains and amyloid fibrillogenesis in monolayers of human fibrocytes. Journal of Molecular Recognition. Jul. 2000;13(4):198-212. [pmid: 10931557]. Not relevant re test, population, diagnosis, or comparison
90 Hasegawa M, Kondo F, Yamamoto K, et al. Evaluation of blood purification and bortezomib plus dexamethasone therapy for the treatment of acute renal failure due to myeloma cast nephropathy. Therapeutic Apheresis & Dialysis: Official Peer-Reviewed Journal of the International Society for Apheresis, the Japanese Society for Apheresis, the Japanese Society for Dialysis Therapy. Oct. 2010;14(5):451-56. Not relevant re test, population, diagnosis, or comparison
91 Hasserjian RP, Goodman HJ, Lachmann HJ, et al. Bone marrow findings correlate with clinical outcome in systemic AL amyloidosis patients. Histopathology. Apr. 2007;50(5):567-73. [pmid: 17394492]. Not relevant re test, population, diagnosis, or comparison
92 Hassoun H, Flombaum C, D'Agati VD, et al. High-dose melphalan and auto-SCT in patients with monoclonal Ig deposition disease. Bone Marrow Transplantation. Sep. 2008;42(6):405-12. [pmid: 18574442]. Not relevant re test, population, diagnosis, or comparison
93 Hatada EN, Chen-Kiang S, Scheidereit C. Interaction and functional interference of C/EBPbeta with octamer factors in immunoglobulin gene transcription. European Journal of Immunology. Jan. 2000;30(1):174-84. [pmid: 10602039]. Not relevant re test, population, diagnosis, or comparison
94 Hazenberg BP, van G II, Bijzet J, et al. Diagnostic and therapeutic approach of systemic amyloidosis. [Review] [36 refs]. Netherlands Journal of Medicine. Apr. 2004;62(4):121-28. [pmid: 15255082]. Narrative review or commentary
95 Hazenberg BP, van Rijswijk MH, Piers DA, et al. Diagnostic performance of 123I-labeled serum amyloid P component scintigraphy in patients with amyloidosis. American Journal of Medicine. Apr. 2006;119(4):355-24. [pmid: 16564782]. Not relevant re test, population, diagnosis, or comparison
96 Haznedar R, Aki SZ, Akdemir OU, et al. Value of 18F-fluorodeoxyglucose uptake in positron emission tomography/computed tomography in predicting survival in multiple myeloma. European Journal of Nuclear Medicine & Molecular Imaging. Jun. 2011;38(6):1046-53. [pmid: 21287167]. Not relevant re test, population, diagnosis, or comparison
97 Herrmann SM, Gertz MA, Stegall MD, et al. Long-term outcomes of patients with light chain amyloidosis (AL) after renal transplantation with or without stem cell transplantation. Nephrology Dialysis Transplantation. Jun. 2011;26(6):2032-36. Not relevant re test, population, diagnosis, or comparison
98 Herzum I, Renz H, Wahl HG. Immunochemical quantification of free light chains in urine. Clin Chem. Jun. 2005;51(6):1033-35. [pmid: 15914789]. Not relevant re test, population, diagnosis, or comparison
99 Hiatt A, Pauly M. Monoclonal antibodies from plants: a new speed record. Proceedings of the National Academy of Sciences of the United States of America. Oct. 3. 2006;103(40):14645-46. [pmid: 17000998]. Narrative review or commentary
100 Hill PG, Forsyth JM, Rai B, et al. Serum free light chains: an alternative to the urine Bence Jones proteins screening test for monoclonal gammopathies. Clin Chem. Sep. 2006;52(9):1743-48. [pmid: 16858075]. Not relevant re test, population, diagnosis, or comparison
101 Hofmann W, Garbrecht M, Bradwell AR, et al. A new concept for detection of Bence Jones proteinuria in patients with monoclonal gammopathy. Clinical Laboratory. 2004;50(3-4):181-85. [pmid: 15074473]. Not relevant re test, population, diagnosis, or comparison
102 Holding S, Spradbery D, Hoole R, et al. Use of serum free light chain analysis and urine protein electrophoresis for detection of monoclonal gammopathies. Clinical Chemistry & Laboratory Medicine. Jan. 2011;49(1):83-88. [pmid: 20961192]. Not relevant re test, population, diagnosis, or comparison
103 Hopper JE, Golbus J, Meyer C, et al. Urine free light chains in SLE: clonal markers of B-cell activity and potential link to in vivo secreted Ig. Journal of Clinical Immunology. Mar. 2000;20(2):123-37. [pmid: 10821464]. Not relevant re test, population, diagnosis, or comparison
104 Hsi ED, Hoeltge G, Tubbs RR. Biclonal chronic lymphocytic leukemia. American Journal of Clinical Pathology. Jun. 2000;113(6):798-804. [pmid: 10874880]. Not relevant re test, population, diagnosis, or comparison
105 Hummel M, Stein H. Clinical relevance of immunoglobulin mutation analysis. [Review] [61 refs]. Current Opinion in Oncology. Sep. 2000;12(5):395-402. [pmid: 10975545]. Not relevant re test, population, diagnosis, or comparison
106 Hussein MA, Juturi JV, Rybicki L, et al. Etanercept therapy in patients with advanced primary amyloidosis. Medical Oncology. 2003;20(3):283-90. [pmid: 14514978]. Not relevant re test, population, diagnosis, or comparison
107 Hutchison C, Bridoux F, Fermand JP. Renal improvement in myeloma with plasma exchange. New England Journal of Medicine. Sep. 15. 2011;365(11):1061. [pmid: 21916654]. Letter without data
108 Hutchison CA, Cockwell P, Reid S, et al. Efficient removal of immunoglobulin free light chains by hemodialysis for multiple myeloma: in vitro and in vivo studies. Journal of the American Society of Nephrology. Mar. 2007;18(3):886-95. [pmid: 17229909]. Not relevant re test, population, diagnosis, or comparison
109 Hutchison CA, Harding S, Hewins P, et al. Quantitative assessment of serum and urinary polyclonal free light chains in patients with chronic kidney disease. Clinical Journal of The American Society of Nephrology: CJASN. Nov. 2008;3(6):1684-90. [pmid: 18945993]. Not relevant re test, population, diagnosis, or comparison
110 Hutchison CA, Plant T, Drayson M, et al. Serum free light chain measurement aids the diagnosis of myeloma in patients with severe renal failure. BMC Nephrology. 2008;9:11. [pmid: 18808676]. Not relevant re test, population, diagnosis, or comparison
111 Hutchison CA, Bradwell AR, Cook M, et al. Treatment of acute renal failure secondary to multiple myeloma with chemotherapy and extended high cut-off hemodialysis. Clinical Journal of The American Society of Nephrology: CJASN. Apr. 2009;4(4):745-54. [pmid: 19339414]. Not relevant re test, population, diagnosis, or comparison
112 Hutchison CA. Reduction of serum free light chains predict renal recovery. Annals of Hematology. Jun. 2010;89(6):627-28. [pmid: 19784650]. Letter without data
113 Hutchison CA, Cockwell P, Stringer S, et al. Early reduction of serum-free light chains associates with renal recovery in myeloma kidney. Journal of the American Society of Nephrology. Jun. 2011;22(6):1129-36. [pmid: 21511832]. Not relevant re test, population, diagnosis, or comparison
114 Iggo N, Littlewood T, Winearls CG. Prospects for effective treatment of AL amyloidosis?. Qjm. May. 2000;93(5):257-60. [pmid: 10825400]. Not relevant re test, population, diagnosis, or comparison
115 Invernizzi R, Palladini G, Benatti C, et al. Bone marrow amyloidosis. Haematologica. May. 2006;91(5:Suppl). Suppl. Study of single case series
116 Itzykson R, Le Garff-Tavernier M, Katsahian S, et al. Serum-free light chain elevation is associated with a shorter time to treatment in Waldenstrom's macroglobulinemia. Haematologica. May. 2008;93(5):793-94. [pmid: 18450739]. Not relevant re test, population, diagnosis, or comparison
117 Jacobs JF, Joosten I, Klasen IS. Detecting only light chains, now what?. Clin Chem. Aug. 2010;56(8):1368. [pmid: 20668174]. Not relevant re test, population, diagnosis, or comparison
118 Jagannath S. Value of serum free light chain testing for the diagnosis and monitoring of monoclonal gammopathies in hematology. Clinical Lymphoma & Myeloma. Sep. 2007;7(8):518-23. [pmid: 18021469]. Narrative review or commentary
119 Jaskowski TD, Litwin CM, Hill HR. Detection of kappa and lambda light chain monoclonal proteins in human serum: automated immunoassay versus immunofixation electrophoresis. Clinical & Vaccine Immunology: CVI. Feb. 2006;13(2):277-80. [pmid: 16467338]. Not relevant re test, population, diagnosis, or comparison
120 Jena PK, Liu AH, Smith DS, et al. Sequence heterogeneity in Ig kappa transcripts from single B lymphocytes. Molecular Immunology. Apr. 2000;37(6):265-72. [pmid: 11000400]. Not relevant re test, population, diagnosis, or comparison
121 Kaleem Z, Zehnbauer BA, White G, et al. Lack of expression of surface immunoglobulin light chains in B-cell non-Hodgkin lymphomas. American Journal of Clinical Pathology. Mar. 2000;113(3):399-405. [pmid: 10705821]. Not relevant re test, population, diagnosis, or comparison
122 Kang SY, Suh JT, Lee HJ, et al. Clinical usefulness of free light chain concentration as a tumor marker in multiple myeloma. Annals of Hematology. Sep. 2005;84(9):588-93. [pmid: 15883850]. Not relevant re test, population, diagnosis, or comparison
123 Kaplan JS, Horowitz GL. Twenty-four-hour Bence-Jones protein determinations: can we ensure accuracy?. Archives of Pathology & Laboratory Medicine. Aug. 2011;135(8):1048-51. [pmid: 21809998]. Not relevant re test, population, diagnosis, or comparison
124 Katzmann JA, Clark RJ, Abraham RS, et al. Serum reference intervals and diagnostic ranges for free kappa and free lambda immunoglobulin light chains: relative sensitivity for detection of monoclonal light chains. Clin Chem. Sep. 2002;48(9):1437-44. [pmid: 12194920]. Not relevant re test, population, diagnosis, or comparison
125 Katzmann JA, Abraham RS, Dispenzieri A, et al. Diagnostic performance of quantitative kappa and lambda free light chain assays in clinical practice. Clin Chem. May. 2005;51(5):878-81. [pmid: 15774572]. Not relevant re test, population, diagnosis, or comparison
126 Katzmann JA. Serum free light chain specificity and sensitivity: a reality check. Clin Chem. Sep. 2006;52(9):1638-39. [pmid: 16940461]. Narrative review or commentary
127 Katzmann JA, Dispenzieri A, Kyle RA, et al. Elimination of the need for urine studies in the screening algorithm for monoclonal gammopathies by using serum immunofixation and free light chain assays. Mayo Clinic Proceedings. Dec. 2006;81(12):1575-78. [pmid: 17165636]. Not relevant re test, population, diagnosis, or comparison
128 Katzmann JA, Kyle RA, Benson J, et al. Screening panels for detection of monoclonal gammopathies. Clin Chem. Aug. 2009;55(8):1517-22. [pmid: 19520758]. Not relevant re test, population, diagnosis, or comparison
129 Katzmann JA, Stankowski-Drengler TJ, Kyle RA, et al. Specificity of serum and urine protein electrophoresis for the diagnosis of monoclonal gammopathies. Clin Chem. Dec. 2010;56(12):1899-900. [pmid: 20844060]. Not relevant re test, population, diagnosis, or comparison
130 Keren DF. Heavy/Light-chain analysis of monoclonal gammopathies. Clin Chem. Sep. 2009;55(9):1606-08. [pmid: 19589841]. Not relevant re test, population, diagnosis, or comparison
131 Khalifa MB, Weidenhaupt M, Choulier L, et al. Effects on interaction kinetics of mutations at the VH-VL interface of Fabs depend on the structural context. Journal of Molecular Recognition. May. 2000;13(3):127-39. [pmid: 10867708]. Not relevant re test, population, diagnosis, or comparison
132 Kim Y, Wall JS, Meyer J, et al. Thermodynamic modulation of light chain amyloid fibril formation. Journal of Biological Chemistry. Jan. 21. 2000;275(3):1570-74. [pmid: 10636846]. Not relevant re test, population, diagnosis, or comparison
133 Kleeberg L, Morgera S, Jakob C, et al. Novel renal replacement strategies for the elimination of serum free light chains in patients with kappa light chain nephropathy. European Journal of Medical Research. Feb. 18. 2009;14(2):47-54. [pmid: 19258212]. Not relevant re test, population, diagnosis, or comparison
134 Klein CJ, Vrana JA, Theis JD, et al. Mass spectrometric-based proteomic analysis of amyloid neuropathy type in nerve tissue. Archives of Neurology. Feb. 2011;68(2):195-99. [pmid: 20937937]. Not relevant re test, population, diagnosis, or comparison
135 Kuci H, Ebert MP, Rocken C. Anti-lambda-light chain-peptide antibodies are suitable for the immunohistochemical classification of AL amyloid. Histology & Histopathology. Apr. 2007;22(4):379-87. [pmid: 17290348]. Not relevant re test, population, diagnosis, or comparison
136 Kuhnemund A, Liebisch P, Bauchmuller K, et al. ‘Light-chain escape-multiple myeloma’-an escape phenomenon from plateau phase: report of the largest patient series using LC-monitoring. Journal of Cancer Research & Clinical Oncology. Mar. 2009;135(3):477-84. [pmid: 18802723]. Not relevant re test, population, diagnosis, or comparison
137 Kumar S, Dispenzieri A, Gertz MA. High-dose melphalan versus melphalan plus dexamethasone for AL amyloidosis. New England Journal of Medicine. Jan. 3. 2008;358(1):91-93. [pmid: 18172183]. Letter without data
138 Kumar S, Dispenzieri A, Katzmann JA, et al. Serum immunoglobulin free light-chain measurement in primary amyloidosis: prognostic value and correlations with clinical features. Blood. Dec. 9. 2010;116(24):5126-29. [pmid: 20798235]. Not relevant re test, population, diagnosis, or comparison
139 Kumar S, Zhang L, Dispenzieri A, et al. Relationship between elevated immunoglobulin free light chain and the presence of IgH translocations in multiple myeloma. Leukemia. Aug. 2010;24(8):1498-505. [pmid: 20520636]. Not relevant re test, population, diagnosis, or comparison
140 Kumar SK, Dispenzieri A, Lacy MQ, et al. Changes in serum-free light chain rather than intact monoclonal immunoglobulin levels predicts outcome following therapy in primary amyloidosis. American Journal of Hematology. Mar. 2011;86(3):251-55. [pmid: 21328431]. Not relevant re test, population, diagnosis, or comparison
141 Kyle RA, Gertz MA, Witzig TE, et al. Review of 1027 patients with newly diagnosed multiple myeloma. Mayo Clinic Proceedings. Jan. 2003;78(1):21-33. [pmid: 12528874]. Not relevant re test, population, diagnosis, or comparison
142 Kyle RA. New strategies for MGUS and smoldering multiple myeloma. Clinical Advances in Hematology & Oncology. 2004;2(8):507. [pmid: 16163229]. Not relevant re test, population, diagnosis, or comparison
143 Kyle RA, Rajkumar SV. Monoclonal gammopathy of undetermined significance. [Review] [103 refs]. Clinical Lymphoma & Myeloma. Sep. 2005;6(2):102-14. [pmid: 16231848]. Narrative review or commentary
144 Kyle RA, Rajkumar SV. Monoclonal gammopathy of undetermined significance and smouldering multiple myeloma: emphasis on risk factors for progression. [Review] [84 refs]. British Journal of Haematology. Dec. 2007;139(5):730-43. [pmid: 18021088]. Narrative review or commentary
145 Kyle RA, Buadi F, Rajkumar SV. Management of monoclonal gammopathy of undetermined significance (MGUS) and smoldering multiple myeloma (SMM). [Review]. Oncology (Williston Park). Jun. 2011;25(7):578-86. [pmid: 21888255]. Narrative review or commentary
146 Lachmann HJ, Wechalekar AD, Gillmore JD. High-dose melphalan versus melphalan plus dexamethasone for AL amyloidosis. New England Journal of Medicine. 2008;358(1):91-92. [pmid: 18175386]. Letter without data
147 Lae ME, Vencio EF, Inwards CY, et al. Myeloma of the jaw bones: a clinicopathologic study of 33 cases. Head & Neck. May. 2003;25(5):373-81. [pmid: 12692874]. Not relevant re test, population, diagnosis, or comparison
148 Le BT, Bengoufa D, Benlakehal M, et al. Urinary free light chain analysis by the Freelite immunoassay: a preliminary study in multiple myeloma. Clinical Biochemistry. Oct. 2002;35(7):565-67. [pmid: 12493586]. Not relevant re test, population, diagnosis, or comparison
149 Lee LN, Jan IS, Tien HF, et al. Laboratory and clinical characterization of monoclonal gammopathy in Taiwanese. Journal of the Formosan Medical Association. Feb. 2002;101(2):91-97. [pmid: 12099210]. Not relevant re test, population, diagnosis, or comparison
150 Lee MS, Lee GM. Hyperosmotic pressure enhances immunoglobulin transcription rates and secretion rates of KR12H-2 transfectoma. Biotechnology & Bioengineering. May. 5. 2000;68(3):260-68. [pmid: 10745194]. Not relevant re test, population, diagnosis, or comparison
151 Lee SS, Greenberg A, Hsu E. Evolution and somatic diversification of immunoglobulin light chains. [Review] [49 refs]. Current Topics in Microbiology & Immunology. 2000;248:285-300. [pmid: 10793483]. Not relevant re test, population, diagnosis, or comparison
152 Leers MP, Theunissen PH, Ramaekers FC, et al. Clonality assessment of lymphoproliferative disorders by multiparameter flow cytometry of paraffin-embedded tissue: an additional diagnostic tool in surgical pathology. Human Pathology. Apr. 2000;31(4):422-27. [pmid: 10821487]. Not relevant re test, population, diagnosis, or comparison
153 Legg A, Hobbs JA, Mead GP, et al. Monoclonal vs polyclonal free light chain assays. American Journal of Clinical Pathology. 2009;131(6):901-02. [pmid: 19461100]. Letter without data
154 Leleu X, Moreau AS, Weller E, et al. Serum immunoglobulin free light chain correlates with tumor burden markers in Waldenstrom macroglobulinemia. Leukemia & Lymphoma. Jun. 2008;49(6):1104-07. [pmid: 18452095]. Not relevant re test, population, diagnosis, or comparison
155 Leleu X, Xie W, Bagshaw M, et al. The role of serum immunoglobulin free light chain in response and progression in waldenstrom macroglobulinemia. Clinical Cancer Research. May. 1. 2011;17(9):3013-18. [pmid: 21415221]. Not relevant re test, population, diagnosis, or comparison
156 Leung N, Lager DJ, Gertz MA, et al. Long-term outcome of renal transplantation in light-chain deposition disease. American Journal of Kidney Diseases. Jan. 2004;43(1):147-53. [pmid: 14712438]. Not relevant re test, population, diagnosis, or comparison
157 Leung N, Gertz MA, Zeldenrust SR, et al. Improvement of cast nephropathy with plasma exchange depends on the diagnosis and on reduction of serum free light chains. Kidney International. Jun. 2008;73(11):1282-88. [pmid: 18385667]. Not relevant re test, population, diagnosis, or comparison
158 Levine MH, Haberman AM, Sant'Angelo DB, et al. A B-cell receptor-specific selection step governs immature to mature B cell differentiation. Proceedings of the National Academy of Sciences of the United States of America. Mar. 14. 2000;97(6):2743-48. [pmid: 10688906]. Not relevant re test, population, diagnosis, or comparison
159 Levinson SS. Urine protein electrophoresis and immunofixation electrophoresis supplement one another in characterizing proteinuria. Annals of Clinical & Laboratory Science. Jan. 2000;30(1):79-84. [pmid: 10678588]. Not relevant re test, population, diagnosis, or comparison
160 Levinson SS. Polyclonal free light chain of Ig may interfere with interpretation of monoclonal free light chain / ratio. Annals of Clinical & Laboratory Science. 2010;40(4):348-53. [pmid: 20947809]. Not relevant re test, population, diagnosis, or comparison
161 Levinson SS. Hook effect with lambda free light chain in serum free light chain assay. Clinica Chimica Acta. Nov. 11. 2010;411(21-22):1834-36. Study of single case series
162 Li SL, Liang SJ, Guo N, et al. Single-chain antibodies against human insulin-like growth factor I receptor: expression, purification, and effect on tumor growth. Cancer Immunology, Immunotherapy. Jul. 2000;49(4-5):243-52. Not relevant re test, population, diagnosis, or comparison
163 Li Y, Li H, Smith-Gill SJ, et al. Three-dimensional structures of the free and antigen-bound Fab from monoclonal antilysozyme antibody HyHEL-63(,). Biochemistry. May. 30. 2000;39(21):6296-309. [pmid: 10828942]. Not relevant re test, population, diagnosis, or comparison
164 Lin J, Markowitz GS, Valeri AM, et al. Renal monoclonal immunoglobulin deposition disease: the disease spectrum. Journal of the American Society of Nephrology. Jul. 2001;12(7):1482-92. [pmid: 11423577]. Not relevant re test, population, diagnosis, or comparison
165 Liu HY, Luo XM, Zhou SH, et al. Prognosis and expression of lambda light chains in solitary extramedullary plasmacytoma of the head and neck: two case reports and a literature review. Journal of International Medical Research. Jan. 2010;38(1):282-88. [pmid: 20233540]. Not relevant re test, population, diagnosis, or comparison
166 Lueck N, Agrawal YP. Lack of utility of free light chain-specific antibodies in the urine immunofixation test. Clin Chem. May. 2006;52(5):906-07. [pmid: 16638965]. Not relevant re test, population, diagnosis, or comparison
167 Lundin J, Osterborg A, Bjorkholm M, et al. Phase II study of cyclophosphamide, interferon-alpha and betamethasone (CIB) as induction therapy for patients 60-75 years of age with multiple myeloma stages II and III. Hematology Journal. 2003;4(4):248-52. [pmid: 12872149]. Not relevant re test, population, diagnosis, or comparison
168 Ma ES, Lee ET. A case of IgM paraproteinemia in which serum free light chain values were within reference intervals. Clin Chem. Feb. 2007;53(2):362-63. [pmid: 17259251]. Study of a single case
169 Madan S, Dispenzieri A, Lacy MQ, et al. Clinical features and treatment response of light chain (AL) amyloidosis diagnosed in patients with previous diagnosis of multiple myeloma. Mayo Clinic Proceedings. Mar. 2010;85(3):232-38. [pmid: 20194151]. Not relevant re test, population, diagnosis, or comparison
170 Maisnar V, Tichy M, Stulik J, et al. The problems of proteinuria measurement in urine with presence of Bence Jones protein. Clinical Biochemistry. Apr. 2011;44(5-6):403-05. [pmid: 21291878]. Study of a single case
171 Marien G, Oris E, Bradwell AR, et al. Detection of monoclonal proteins in sera by capillary zone electrophoresis and free light chain measurements. Clin Chem. Sep. 2002;48(9):1600-01. [pmid: 12194945]. Not relevant re test, population, diagnosis, or comparison
172 Markey GM, Kettle P, Morris TC, et al. Quantitation of monoclonal plasma cells in bone marrow biopsies in plasma cell dyscrasia. Analytical Cellular Pathology. 2003;25(4):167-71. [pmid: 14501083]. Not relevant re test, population, diagnosis, or comparison
173 Marshall G, Tate J, Mollee P. Borderline high serum free light chain kappa/lambda ratios are seen not only in dialysis patients but also in non-dialysis-dependent renal impairment and inflammatory states. American Journal of Clinical Pathology. Aug. 2009;132(2):309. [pmid: 19605825]. Not relevant re test, population, diagnosis, or comparison
174 Martinez-Sanchez P, Montejano L, Sarasquete ME, et al. Evaluation of minimal residual disease in multiple myeloma patients by fluorescent-polymerase chain reaction: the prognostic impact of achieving molecular response. British Journal of Haematology. Sep. 2008;142(5):766-74. [pmid: 18637804]. Not relevant re test, population, diagnosis, or comparison
175 Matsuda M, Yamada T, Gono T, et al. Serum levels of free light chain before and after chemotherapy in primary systemic AL amyloidosis. Internal Medicine. May. 2005;44(5):428-33. [pmid: 15942088]. Not relevant re test, population, diagnosis, or comparison
176 Matsue K, Fujiwara H, Iwama K, et al. Reversal of dialysis-dependent renal failure in patients with advanced multiple myeloma: single institutional experiences over 8 years. Annals of Hematology. Mar. 2010;89(3):291-97. [pmid: 19693498]. Not relevant re test, population, diagnosis, or comparison
177 Maurer MJ, Micallef IN, Cerhan JR, et al. Elevated serum free light chains are associated with event-free and overall survival in two independent cohorts of patients with diffuse large B-cell lymphoma. Journal of Clinical Oncology. Apr. 20. 2011;29(12):1620-26. [pmid: 21383282]. Not relevant re test, population, diagnosis, or comparison
178 Maurer MJ, Cerhan JR, Katzmann JA, et al. Monoclonal and polyclonal serum free light chains and clinical outcome in chronic lymphocytic leukemia. Blood. Sep. 8. 2011;118(10):2821-26. [pmid: 21765023]. Not relevant re test, population, diagnosis, or comparison
179 Mayo MW, Baldwin AS. The transcription factor NF-kappaB: control of oncogenesis and cancer therapy resistance. [Review] [96 refs]. Biochimica et Biophysica Acta. Mar. 27. 2000;1470(2):M55-M62. [pmid: 10722927]. Not relevant re test, population, diagnosis, or comparison
180 McCudden CR, Voorhees PM, Hainsworth SA, et al. Interference of monoclonal antibody therapies with serum protein electrophoresis tests. Clin Chem. Dec. 2010;56(12):1897-99. [pmid: 20940329]. Study of a single case
181 Mead GP, Carr-Smith HD, Drayson MT, et al. Detection of Bence Jones myeloma and monitoring of myeloma chemotherapy using immunoassays specific for free immunoglobulin light chains. Clinical Laboratory. 2003;49(1-2):25-27. [pmid: 12593472]. Not relevant re test, population, diagnosis, or comparison
182 Mead GP, Drayson MT, Carr-Smith HD, et al. Measurement of immunoglobulin free light chains in serum. Clin Chem. 2003;49(11):1957-58. [pmid: 14578337]. Letter without data
183 Mead GP, Carr-Smith HD, Drayson MT, et al. Serum free light chains for monitoring multiple myeloma. British Journal of Haematology. Aug. 2004;126(3):348-54. [pmid: 15257706]. Not relevant re test, population, diagnosis, or comparison
184 Mead GP, Carr-Smith HD, Bradwell AR. Free light chains. Annals of Clinical Biochemistry. Jul. 2008;45(Pt:4):4. Letter without data
185 Mead GP, Drayson MT. Sensitivity of serum free light chain measurement of residual disease in multiple myeloma patients. Blood. Aug. 20. 2009;114(8):1717. [pmid: 19696211]. Letter without data
186 Mead GP, Carr-Smith HD. Overestimation of serum kappa free light chain concentration by immunonephelometry. Clin Chem. 2010;56(9):1503-04. [pmid: 20581080]. Letter without data
187 Melchers F, ten BE, Seidl T, et al. Repertoire selection by pre-B-cell receptors and B-cell receptors, and genetic control of B-cell development from immature to mature B cells. [Review] [69 refs]. Immunological Reviews. Jun. 2000;175:33-46. [pmid: 10933589]. Not relevant re test, population, diagnosis, or comparison
188 Melmed GM, Fenves AZ, Stone MJ. Urinary findings in renal light chain-derived amyloidosis and light chain deposition disease. Clinical Lymphoma & Myeloma. Jun. 2009;9(3):234-38. [pmid: 19525193]. Not relevant re test, population, diagnosis, or comparison
189 Menetski JP. The structure of the nuclear factor-kappaB protein-DNA complex varies with DNA-binding site sequence. Journal of Biological Chemistry. Mar. 17. 2000;275(11):7619-25. [pmid: 10713070]. Not relevant re test, population, diagnosis, or comparison
190 Merlini G. Serum-free light chain analysis: works in progress. Clinical Chemistry & Laboratory Medicine. 2009;47(9):1021-22. [pmid: 19728842]. Narrative review or commentary
191 Merlini G, Seldin DC, Gertz MA. Amyloidosis: pathogenesis and new therapeutic options. [Review]. Journal of Clinical Oncology. May. 10. 2011;29(14):1924-33. [pmid: 21483018]. Narrative review or commentary
192 Michael M, Kastritis E, Delimpassi S, et al. Clinical characteristics and outcome of primary systemic light-chain amyloidosis in Greece. Clinical lymphoma, myeloma & leukemia. Feb. 2010;10(1):56-61. Not relevant re test, population, diagnosis, or comparison
193 Mignot A, Varnous S, Redonnet M, et al. Heart transplantation in systemic (AL) amyloidosis: a retrospective study of eight French patients. Archives of cardiovascular diseases. Sep. 2008;101(9):523-32. [pmid: 19041836]. Not relevant re test, population, diagnosis, or comparison
194 Min CK, Lee MJ, Eom KS, et al. Bortezomib in combination with conventional chemotherapeutic agents for multiple myeloma compared with bortezomib alone. Japanese Journal of Clinical Oncology. Dec. 2007;37(12):961-68. [pmid: 18156171]. Not relevant re test, population, diagnosis, or comparison
195 Monge M, Chauveau D, Cordonnier C, et al. Localized amyloidosis of the genitourinary tract: report of 5 new cases and review of the literature. [Review]. Medicine. May. 2011;90(3):212-22. [pmid: 21512410]. Not relevant re test, population, diagnosis, or comparison
196 Monson NL, Dorner T, Lipsky PE. Targeting and selection of mutations in human Vlambda rearrangements. European Journal of Immunology. Jun. 2000;30(6):1597-605. [pmid: 10898495]. Not relevant re test, population, diagnosis, or comparison
197 Morris KL, Tate JR, Gill D, et al. Diagnostic and prognostic utility of the serum free light chain assay in patients with AL amyloidosis. Internal Medicine Journal. Jul. 2007;37(7):456-63. [pmid: 17547724]. Not relevant re test, population, diagnosis, or comparison
198 Mosbauer U, Ayuk F, Schieder H, et al. Monitoring serum free light chains in patients with multiple myeloma who achieved negative immunofixation after allogeneic stem cell transplantation. Haematologica. Feb. 2007;92(2):275-76. [pmid: 17296589]. Not relevant re test, population, diagnosis, or comparison
199 Moscetti A, Saltarelli F, Bianchi MP, et al. Quick response to bortezomib plus dexamethasone in a patient with AL amyloidosis in first relapse. Amyloid. Jun. 2011;18. Suppl-9. Study of a single case
200 Muljo SA, Schlissel MS. Pre-B and pre-T-cell receptors: conservation of strategies in regulating early lymphocyte development. [Review] [129 refs]. Immunological Reviews. Jun. 2000;175:80-93. [pmid: 10933593]. Not relevant re test, population, diagnosis, or comparison
201 Murata K, Clark RJ, Lockington KS, et al. Sharply increased serum free light-chain concentrations after treatment for multiple myeloma. Clin Chem. Jan. 2010;56(1):16-18. [pmid: 20040623]. Study of a single case
202 Mussap M, Ponchia S, Zaninotto M, et al. Evaluation of a new capillary zone electrophoresis system for the identification and typing of Bence Jones Protein. Clinical Biochemistry. Feb. 2006;39(2):152-59. [pmid: 16337932]. Not relevant re test, population, diagnosis, or comparison
203 Nakano T, Nagata A, Takahashi H. Ratio of urinary free immunoglobulin light chain kappa to lambda in the diagnosis of Bence Jones proteinuria. Clinical Chemistry & Laboratory Medicine. Apr. 2004;42(4):429-34. [pmid: 15147154]. Not relevant re test, population, diagnosis, or comparison
204 Nakao M, Janssen JW, Bartram CR. Duplex PCR facilitates the identification of immunoglobulin kappa (IGK) gene rearrangements in acute lymphoblastic leukemia. Leukemia. Jan. 2000;14(1):218-19. [pmid: 10637501]. Not relevant re test, population, diagnosis, or comparison
205 Nemazee D, Weigert M. Revising B cell receptors. [Review] [40 refs]. Journal of Experimental Medicine. Jun. 5. 2000;191(11):1813-17. [pmid: 10839798]. Not relevant re test, population, diagnosis, or comparison
206 Nemazee D. Receptor editing in B cells. [Review] [231 refs]. Advances in Immunology. 2000;74:89-126. [pmid: 10605605]. Not relevant re test, population, diagnosis, or comparison
207 Nowrousian MR, Brandhorst D, Sammet C, et al. Serum free light chain analysis and urine immunofixation electrophoresis in patients with multiple myeloma. Clinical Cancer Research. Dec. 15. 2005;11(24:Pt 1):t-14. Not relevant re test, population, diagnosis, or comparison
208 Ohnishi K, Shimizu T, Karasuyama H, et al. The identification of a nonclassical cadherin expressed during B cell development and its interaction with surrogate light chain. Journal of Biological Chemistry. Oct. 6. 2000;275(40):31134-44. [pmid: 10906147]. Not relevant re test, population, diagnosis, or comparison
209 Olteanu H, Wang HY, Chen W, et al. Immunophenotypic studies of monoclonal gammopathy of undetermined significance. BMC Clinical Pathology. 2008;8:13. [pmid: 19040735]. Not relevant re test, population, diagnosis, or comparison
210 Ondrejka SL, Lai R, Smith SD, et al. Indolent mantle cell leukemia: a clinicopathological variant characterized by isolated lymphocytosis, interstitial bone marrow involvement, kappa light chain restriction, and good prognosis. Haematologica. Aug. 2011;96(8):1121-27. [pmid: 21508124]. Not relevant re test, population, diagnosis, or comparison
211 Oyeyinka GO, Ofei V, Maddy SQ, et al. Homogeneous immunoglobulins in Ghanaians living in Accra, Ghana. African Journal of Medicine & Medical Sciences. Dec. 2004;33(4):311-16. [pmid: 15977437]. Not relevant re test, population, diagnosis, or comparison
212 Ozaki S. Role of immunoglobulin light chains in Al amyloidosis. Internal Medicine. May. 2005;44(5):399-400. [pmid: 15942079]. Narrative review or commentary
213 Ozsan GH, Dispenzieri A. Serum free light chain analysis in multiple myeloma and plasma cell dyscrasias. Expert Review of Clinical Immunology. Jan. 2011;7(1):65-73. [pmid: 21162651]. Not relevant re test, population, diagnosis, or comparison
214 Palladini G, Lavatelli F, Russo P, et al. Circulating amyloidogenic free light chains and serum N-terminal natriuretic peptide type B decrease simultaneously in association with improvement of survival in AL. Blood. May. 15. 2006;107(10):3854-58. [pmid: 16434487]. Not relevant re test, population, diagnosis, or comparison
215 Palladini G, Perfetti V, Merlini G. Therapy and management of systemic AL (primary) amyloidosis. [Review] [41 refs]. Swiss Medical Weekly. Nov. 11. 2006;136(45-46):715-20. [pmid: 17183435]. Narrative review or commentary
216 Palladini G, Russo P, Nuvolone M, et al. Treatment with oral melphalan plus dexamethasone produces long-term remissions in AL amyloidosis. Blood. Jul. 15. 2007;110(2):787-88. [pmid: 17606766]. Not relevant re test, population, diagnosis, or comparison
217 Palladini G, Russo P, Bosoni T, et al. AL amyloidosis associated with IgM monoclonal protein: a distinct clinical entity. Clinical Lymphoma & Myeloma. Mar. 2009;9(1):80-83. [pmid: 19362981]. Not relevant re test, population, diagnosis, or comparison
218 Palladini G, Russo P, Bosoni T, et al. Identification of amyloidogenic light chains requires the combination of serum-free light chain assay with immunofixation of serum and urine. Clin Chem. Mar. 2009;55(3):499-504. [pmid: 19131635]. Not relevant re test, population, diagnosis, or comparison
219 Park HK, Lee KR, Kim YJ, et al. Prevalence of monoclonal gammopathy of undetermined significance in an elderly urban Korean population. American Journal of Hematology. Sep. 2011;86(9):752-55. [pmid: 21786289]. Not relevant re test, population, diagnosis, or comparison
220 Patil AR, Thomas CJ, Surolia A. Kinetics and the mechanism of interaction of the endoplasmic reticulum chaperone, calreticulin, with monoglucosylated (Glc1Man9GlcNAc2) substrate. Journal of Biological Chemistry. Aug. 11. 2000;275(32):24348-56. [pmid: 10821837]. Not relevant re test, population, diagnosis, or comparison
221 Pattenden RJ, Rogers SY, Wenham PR. Serum free light chains; the need to establish local reference intervals. Annals of Clinical Biochemistry. Nov. 2007;44(Pt:6):6-5. Not relevant re test, population, diagnosis, or comparison
222 Perz JB, Rahemtulla A, Giles C, et al. Long-term outcome of high-dose melphalan and autologous stem cell transplantation for AL amyloidosis. Bone Marrow Transplantation. May. 2006;37(10):937-43. [pmid: 16565738]. Not relevant re test, population, diagnosis, or comparison
223 Pika T, Minarik J, Schneiderka P, et al. The correlation of serum immunoglobulin free light chain levels and selected biological markers in multiple myeloma. Biomedical Papers of the Medical Faculty of Palacky University in Olomouc, Czech Republic. Jun. 2008;152(1):61-64. Not relevant re test, population, diagnosis, or comparison
224 Pinney JH, Lachmann HJ, Bansi L, et al. Outcome in renal Al amyloidosis after chemotherapy. Journal of Clinical Oncology. Feb. 20. 2011;29(6):674-81. [pmid: 21220614]. Not relevant re test, population, diagnosis, or comparison
225 Poshusta TL, Sikkink LA, Leung N, et al. Mutations in specific structural regions of immunoglobulin light chains are associated with free light chain levels in patients with AL amyloidosis. PLoS ONE. [Electronic Resource]. 2009;4(4):e5169. [pmid: 19365555]. Not relevant re test, population, diagnosis, or comparison
226 Pratt G, Mead GP, Godfrey KR, et al. The tumor kinetics of multiple myeloma following autologous stem cell transplantation as assessed by measuring serum-free light chains. Leukemia & Lymphoma. Jan. 2006;47(1):21-28. [pmid: 16321823]. Not relevant re test, population, diagnosis, or comparison
227 Pratt G. The evolving use of serum free light chain assays in haematology. [Review] [72 refs]. British Journal of Haematology. May. 2008;141(4):413-22. [pmid: 18318757]. Narrative review or commentary
228 Pretorius CJ, Ungerer JP, Wilgen U, et al. Screening panels for detection of monoclonal gammopathies: confidence intervals. Clin Chem. 2010;56(4):677-79. [pmid: 20110450]. Letter without data
229 Proulx C, Boyer L, St-Amour I, et al. Higher affinity human D MoAb prepared by light-chain shuffling and selected by phage display. Transfusion. Jan. 2002;42(1):59-65. [pmid: 11896314]. Not relevant re test, population, diagnosis, or comparison
230 Qu X, Zhang L, Fu W, et al. An infrequent relapse of multiple myeloma predominantly manifesting as light chain escape: clinical experience from two Chinese centers. Leukemia & Lymphoma. Oct. 2010;51(10):1844-49. [pmid: 20846099]. Not relevant re test, population, diagnosis, or comparison
231 Qu Z, Zheng X, Wang SX, et al. Clinical and pathological features of renal amyloidosis: an analysis of 32 patients in a single Chinese centre. Nephrology. Feb. 2010;15(1):102-07. [pmid: 20377777]. Not relevant re test, population, diagnosis, or comparison
232 Rajkumar SV, Kyle RA, Therneau TM, et al. Presence of monoclonal free light chains in the serum predicts risk of progression in monoclonal gammopathy of undetermined significance. British Journal of Haematology. Nov. 2004;127(3):308-10. [pmid: 15491291]. Not relevant re test, population, diagnosis, or comparison
233 Rajkumar SV. MGUS and smoldering multiple myeloma: update on pathogenesis, natural history, and management. Hematology. 2005:340-45. [pmid: 16304401]. Narrative review or commentary
234 Rajkumar SV, Kyle RA, Therneau TM, et al. Serum free light chain ratio is an independent risk factor for progression in monoclonal gammopathy of undetermined significance. Blood. Aug. 1. 2005;106(3):812-17. [pmid: 15855274]. Not relevant re test, population, diagnosis, or comparison
235 Rajkumar SV, Dispenzieri A, Kyle RA. Monoclonal gammopathy of undetermined significance, Waldenstrom macroglobulinemia, AL amyloidosis, and related plasma cell disorders: diagnosis and treatment. [Review] [107 refs][Erratum appears in Mayo Clin Proc. 2006 Nov;81(11):1509]. Mayo Clinic Proceedings. May. 2006;81(5):693-703. [pmid: 16706268]. Narrative review or commentary
236 Ramasamy I. Serum free light chain analysis in B-cell dyscrasias. Annals of Clinical & Laboratory Science. 2007;37(3):291-94. [pmid: 17709698]. Not relevant re test, population, diagnosis, or comparison
237 Ramos R, Poveda R, Sarra J, et al. Renal involvement in non-malignant IgM gammopathy. Nephrology Dialysis Transplantation. Feb. 2007;22(2):627-30. Study of a single case
238 Rho L, Qiu L, Strauchen JA, et al. Pulmonary manifestations of light chain deposition disease. [Review] [15 refs]. Respirology. Jul. 2009;14(5):767-70. [pmid: 19659654]. Not relevant re test, population, diagnosis, or comparison
239 Rogoski RR. Serum free light chain assays: detecting plasma cell disorders. Mlo: Medical Laboratory Observer. 2009;41(7):10-16. [pmid: 19685691]. Narrative review or commentary
240 Romanow WJ, Langerak AW, Goebel P, et al. E2A and EBF act in synergy with the V(D)J recombinase to generate a diverse immunoglobulin repertoire in nonlymphoid cells. Molecular Cell. Feb. 2000;5(2):343-53. [pmid: 10882075]. Not relevant re test, population, diagnosis, or comparison
241 Ross DM, To LB, Horvath N. Assessment of early paraprotein response to vincristine-doxorubicin-dexamethasone chemotherapy may help guide therapy in multiple myeloma. Internal Medicine Journal. Sep. 2004;34(9-10):576-78. [pmid: 15482273]. Not relevant re test, population, diagnosis, or comparison
242 Russo P, Palladini G, Foli A, et al. Liver involvement as the hallmark of aggressive disease in light chain amyloidosis: distinctive clinical features and role of light chain type in 225 patients. Amyloid. Jun. 2011;18. Suppl-8. Not relevant re test, population, diagnosis, or comparison
243 Sahara N, Takeshita A, Shigeno K, et al. Clinicopathological and prognostic characteristics of CD56-negative multiple myeloma. British Journal of Haematology. Jun. 2002;117(4):882-85. [pmid: 12060125]. Not relevant re test, population, diagnosis, or comparison
244 Sanchez-Castanon M, Gago M, Fernandez-Fresnedo G, et al. Quantitative assessment of serum free light chains in renal transplantation. Transplantation Proceedings. Oct. 2010;42(8):2861-63. [pmid: 20970552]. Not relevant re test, population, diagnosis, or comparison
245 Sanchorawala V, Skinner M, Quillen K, et al. Long-term outcome of patients with AL amyloidosis treated with high-dose melphalan and stem-cell transplantation. Blood. Nov. 15. 2007;110(10):3561-63. [pmid: 17673601]. Not relevant re test, population, diagnosis, or comparison
246 Schonland SO, Perz JB, Hundemer M, et al. Indications for high-dose chemotherapy with autologous stem cell support in patients with systemic amyloid light chain amyloidosis. Transplantation. Sep. 27. 2005;80(1:Suppl). Suppl-3. Not relevant re test, population, diagnosis, or comparison
247 Seldin DC, Choufani EB, Dember LM, et al. Tolerability and efficacy of thalidomide for the treatment of patients with light chain-associated (AL) amyloidosis. Clinical Lymphoma. Mar. 2003;3(4):241-46. [pmid: 12672274]. Not relevant re test, population, diagnosis, or comparison
248 Seldin DC, Andrea N, Berenbaum I, et al. High-dose melphalan and autologous stem cell transplantation for AL amyloidosis: recent trends in treatment-related mortality and 1-year survival at a single institution. Amyloid. Jun. 2011;18. Suppl-4. Not relevant re test, population, diagnosis, or comparison
249 Seriu T, Hansen-Hagge TE, Stark Y, et al. Immunoglobulin kappa gene rearrangements between the kappa deleting element and Jkappa recombination signal sequences in acute lymphoblastic leukemia and normal hematopoiesis. Leukemia. Apr. 2000;14(4):671-74. [pmid: 10764153]. Not relevant re test, population, diagnosis, or comparison
250 Shaheen SP, Levinson SS. Serum free light chain analysis may miss monoclonal light chains that urine immunofixation electrophoreses would detect. Clinica Chimica Acta. Aug. 2009;406(1-2):162-66. Not relevant re test, population, diagnosis, or comparison
251 Shimojima Y, Matsuda M, Gono T, et al. Correlation between serum levels of free light chain and phenotype of plasma cells in bone marrow in primary AL amyloidosis. Amyloid. Mar. 2005;12(1):33-40. [pmid: 16076609]. Not relevant re test, population, diagnosis, or comparison
252 Sigvardsson M. Overlapping expression of early B-cell factor and basic helix-loop-helix proteins as a mechanism to dictate B-lineage-specific activity of the lambda5 promoter. Molecular & Cellular Biology. May. 2000;20(10):3640-54. [pmid: 10779354]. Not relevant re test, population, diagnosis, or comparison
253 Sikkink LA, Ramirez-Alvarado M. Biochemical and aggregation analysis of Bence Jones proteins from different light chain diseases. Amyloid. Mar. 2008;15(1):29-39. [pmid: 18266119]. Not relevant re test, population, diagnosis, or comparison
254 Sinclair D, Wainwright L. How lab staff and the estimation of free light chains can combine to aid the diagnosis of light chain disease. Clinical Laboratory. 2007;53(5-6):267-71. [pmid: 17605400]. Not relevant re test, population, diagnosis, or comparison
255 Singhal S, Stein R, Vickrey E, et al. The serum-free light chain assay cannot replace 24-hour urine protein estimation in patients with plasma cell dyscrasias. Blood. Apr. 15. 2007;109(8):3611-12. [pmid: 17409349]. Not relevant re test, population, diagnosis, or comparison
256 Singhal S, Vickrey E, Krishnamurthy J, et al. The relationship between the serum free light chain assay and serum immunofixation electrophoresis, and the definition of concordant and discordant free light chain ratios. Blood. Jul. 2. 2009;114(1):38-39. [pmid: 19411633]. Not relevant re test, population, diagnosis, or comparison
257 Siragusa S, Morice W, Gertz MA, et al. Asymptomatic immunoglobulin light chain amyloidosis (AL) at the time of diagnostic bone marrow biopsy in newly diagnosed patients with multiple myeloma and smoldering myeloma. A series of 144 cases and a review of the literature. Annals of Hematology. Jan. 2011;90(1):101-06. [pmid: 20645101]. Not relevant re test, population, diagnosis, or comparison
258 Sirohi B, Powles R, Kulkarni S, et al. Comparison of new patients with Bence-Jones, IgG and IgA myeloma receiving sequential therapy: the need to regard these immunologic subtypes as separate disease entities with specific prognostic criteria. Bone Marrow Transplantation. Jul. 2001;28(1):29-37. [pmid: 11498741]. Not relevant re test, population, diagnosis, or comparison
259 Skinner M. AL amyloidosis: the last 30 years. [Review] [21 refs]. Amyloid. Mar. 2000;7(1):13-14. [pmid: 10842697]. Narrative review or commentary
260 Skinner M, Sanchorawala V, Seldin DC, et al. High-dose melphalan and autologous stem-cell transplantation in patients with AL amyloidosis: an 8-year study. Annals of Internal Medicine. Jan. 20. 2004;140(2):85-93. [pmid: 14734330]. Not relevant re test, population, diagnosis, or comparison
261 Snozek CL, Katzmann JA, Kyle RA, et al. Prognostic value of the serum free light chain ratio in newly diagnosed myeloma: proposed incorporation into the international staging system. Leukemia. Oct. 2008;22(10):1933-37. [pmid: 18596742]. Not relevant re test, population, diagnosis, or comparison
262 Snyder MR, Clark R, Bryant SC, et al. Quantification of urinary light chains. Clin Chem. Oct. 2008;54(10):1744-46. [pmid: 18824580]. Not relevant re test, population, diagnosis, or comparison
263 Song MK, Oh MS, Lee JH, et al. Light chain of natural antibody plays a dominant role in protein antigen binding. Biochemical & Biophysical Research Communications. Feb. 16. 2000;268(2):390-94. [pmid: 10679214]. Not relevant re test, population, diagnosis, or comparison
264 Stankowski-Drengler T, Gertz MA, Katzmann JA, et al. Serum immunoglobulin free light chain measurements and heavy chain isotype usage provide insight into disease biology in patients with POEMS syndrome. American Journal of Hematology. Jun. 2010;85(6):431-34. [pmid: 20513121]. Not relevant re test, population, diagnosis, or comparison
265 Sthaneshwar P, Nadarajan V, Maniam JA, et al. Serum free light chains: diagnostic and prognostic value in multiple myeloma. Clinical Chemistry & Laboratory Medicine. 2009;47(9):1101-07. [pmid: 19728852]. Not relevant re test, population, diagnosis, or comparison
266 Stollar BD. Contributions of antibody VH domains to anti-DNA autoreactivity. [Review] [27 refs]. Clinical Reviews in Allergy & Immunology. Feb. 2000;18(1):41-50. [pmid: 10907106]. Not relevant re test, population, diagnosis, or comparison
267 Stone MJ. Myeloma and macroglobulinemia: what are the criteria for diagnosis?. [Review] [17 refs]. Clinical Lymphoma. Jun. 2002;3(1):23-25. [pmid: 12141951]. Narrative review
268 Suzuki K. Light- and heavy-chain deposition disease (LHCDD): difficulty in diagnosis and treatment. Internal Medicine. Sep. 2005;44(9):915-16. [pmid: 16258202]. Narrative review or commentary
269 Suzuki M, Takemura H, Suzuki H, et al. Light chain determines the binding property of human anti-dsDNA IgG autoantibodies. Biochemical & Biophysical Research Communications. Apr. 29. 2000;271(1):240-43. [pmid: 10777709]. Not relevant re test, population, diagnosis, or comparison
270 Swan N, Skinner M, O'Hara CJ. Bone marrow core biopsy specimens in AL (primary) amyloidosis. A morphologic and immunohistochemical study of 100 cases. American Journal of Clinical Pathology. Oct. 2003;120(4):610-16. [pmid: 14560572]. Not relevant re test, population, diagnosis, or comparison
271 Szczepanski T. Deciphering the immunoglobulin code in multiple myeloma. Haematologica. Jun. 2006;91(6):725B. Narrative review or commentary
272 Tamimi W, Alaskar A, Alassiri M, et al. Monoclonal gammopathy in a tertiary referral hospital. Clinical Biochemistry. Jun. 2010;43(9):709-13. [pmid: 20206156]. Not relevant re test, population, diagnosis, or comparison
273 Tamura M, Milenic DE, Iwahashi M, et al. Structural correlates of an anticarcinoma antibody: identification of specificity-determining residues (SDRs) and development of a minimally immunogenic antibody variant by retention of SDRs only. Journal of Immunology. Feb. 1. 2000;164(3):1432-41. Not relevant re test, population, diagnosis, or comparison
274 Tate J, Mollee P, Gill D. Serum free light chains for monitoring multiple myeloma. British Journal of Haematology. 2005;128(3):405-06. [pmid: 15667546]. Not relevant re test, population, diagnosis, or comparison
275 Tate J, Bazeley S, Sykes S, et al. Quantitative serum free light chain assay--analytical issues. Clinical Biochemist Reviews. Aug. 2009;30(3):131-40. Narrative review or commentary
276 Tate JR, Gill D, Cobcroft R, et al. Practical considerations for the measurement of free light chains in serum. [Review] [19 refs]. Clin Chem. Aug. 2003;49(8):1252-57. [pmid: 12881439]. Narrative review or commentary
277 Tate JR, Mollee P, Dimeski G, et al. Analytical performance of serum free light-chain assay during monitoring of patients with monoclonal light-chain diseases. Clinica Chimica Acta. Feb. 2007;376(1-2):30-36. Not relevant re test, population, diagnosis, or comparison
278 Tazawa K, Matsuda M, Yoshida T, et al. Therapeutic outcome of cyclic VAD (vincristine, doxorubicin and dexamethasone) therapy in primary systemic AL amyloidosis patients. Internal Medicine. 2008;47(17):1517-22. [pmid: 18758127]. Not relevant re test, population, diagnosis, or comparison
279 te VH, Knop I, Stam P, et al. N Latex FLC - new monoclonal high-performance assays for the determination of free light chain kappa and lambda. Clinical Chemistry & Laboratory Medicine. Aug. 2011;49(8):1323-32. [pmid: 21663464]. Not relevant re test, population, diagnosis, or comparison
280 Telio D, Bailey D, Chen C, et al. Two distinct syndromes of lymphoma-associated AL amyloidosis: a case series and review of the literature. [Review]. American Journal of Hematology. Oct. 2010;85(10):805-08. [pmid: 20872959]. Not relevant re test, population, diagnosis, or comparison
281 Thompson JS, Schneider P, Kalled SL, et al. BAFF binds to the tumor necrosis factor receptor-like molecule B cell maturation antigen and is important for maintaining the peripheral B cell population. Journal of Experimental Medicine. Jul. 3. 2000;192(1):129-35. [pmid: 10880534]. Not relevant re test, population, diagnosis, or comparison
282 Thompson LD, Derringer GA, Wenig BM. Amyloidosis of the larynx: a clinicopathologic study of 11 cases. Modern Pathology. May. 2000;13(5):528-35. [pmid: 10824924]. Not relevant re test, population, diagnosis, or comparison
283 Tobin G, Thunberg U, Johnson A, et al. Somatically mutated Ig V(H)3-21 genes characterize a new subset of chronic lymphocytic leukemia. Blood. Mar. 15. 2002;99(6):2262-64. [pmid: 11877310]. Not relevant re test, population, diagnosis, or comparison
284 Tramontano A, Ivanov B, Gololobov G, et al. Inhibition and labeling of enzymes and abzymes by phosphonate diesters. Applied Biochemistry & Biotechnology. 242. Mar. 83(1-3):233-42. [pmid: 10826963]. Not relevant re test, population, diagnosis, or comparison
285 Uljon SN, Richardson PG, Schur PH, et al. Serial serum free light chain measurements do not detect changes in disease status earlier than electrophoretic M-spike measurements in patients with intact immunoglobulin myeloma. Clinica Chimica Acta. Mar. 18. 2011;412(7-8):562-68. Not relevant re test, population, diagnosis, or comparison
286 Usha, Agarwal N, Kumar P. Myeloma in young age. Indian Journal of Pathology & Microbiology. Jul. 2005;48(3):314-17. Not relevant re test, population, diagnosis, or comparison
287 Van De DN, De WO, Eurelings M, et al. Malignant transformation of monoclonal gammopathy of undetermined significance: cumulative incidence and prognostic factors. Leukemia & Lymphoma. Aug. 2001;42(4):609-18. [pmid: 11697489]. Not relevant re test, population, diagnosis, or comparison
288 van der Linden PW, Bergkamp FJ, Gasthuis K, et al. Russell bodies in light chain multiple myeloma. Blood. May. 5. 2011;117(18):4689. [pmid: 21695840]. Not relevant re test, population, diagnosis, or comparison
289 van der KH, Gellad ZF, Owen JA. Disparity in the kinetics of onset of hypermutation in immunoglobulin heavy and light chains. Immunology & Cell Biology. Jun. 2000;78(3):224-37. [pmid: 10849110]. Not relevant re test, population, diagnosis, or comparison
290 van Gameren I, van Rijswijk MH, Bijzet J, et al. Histological regression of amyloid in AL amyloidosis is exclusively seen after normalization of serum free light chain. Haematologica. Aug. 2009;94(8):1094-100. [pmid: 19644141]. Not relevant re test, population, diagnosis, or comparison
291 Van GM, Marien G, Verhoef G, et al. Free light chain testing in follow-up of multiple myeloma. Clinical Chemistry & Laboratory Medicine. 2006;44(8):1044-46. [pmid: 16879076]. Not relevant re test, population, diagnosis, or comparison
292 van RF. Light-chain MGUS: implications for clinical practice. Lancet. May. 15. 2010;375(9727):1670-71. [pmid: 20472153]. Narrative review or commentary
293 Vavrova J, Maisnar V, Tichy M, et al. Interlaboratory study of free monoclonal immunoglobulin light chain quantification. Clinical Chemistry & Laboratory Medicine. Jan. 2011;49(1):89-92. [pmid: 21034251]. Not relevant re test, population, diagnosis, or comparison
294 Vavrova J, Maisnar V, Tichy M, et al. Interlaboratory study of free monoclonal immunoglobulin light chain quantification. Clinical Chemistry & Laboratory Medicine. Jan. 2011;49(1):89-92. [pmid: 21034251]. Not relevant re test, population, diagnosis, or comparison
295 Vermeersch P, Marien G, Bossuyt X. More studies are needed to assess the performance of serum free light chain measurement for the diagnosis of B-cell disorders in routine clinical practice. British Journal of Haematology. 2008;143(1):143-45. [pmid: 18671704]. Letter without data
296 Vermeersch P, Vercammen M, Holvoet A, et al. Use of interval-specific likelihood ratios improves clinical interpretation of serum FLC results for the diagnosis of malignant plasma cell disorders. [Erratum appears in Clin Chim Acta. 2010 Apr 2;411(7-8):613 Note: Broeck, Isabelle Vande [corrected to Vande Broek, Isabelle]]. Clinica Chimica Acta. Dec. 2009;410(1-2):54-58. Not relevant re test, population, diagnosis, or comparison
297 Vescio R. Advances in the diagnosis of multiple myeloma. Clinical Advances in Hematology & Oncology. Apr. 2008;6(4):299-300. [pmid: 18496497]. Narrative review or commentary
298 Vesole DH. Predicting outcomes in multiple myeloma: do we really need another model?. Leukemia & Lymphoma. Jul. 2011;52(7):1170-72. [pmid: 21699380]. Not relevant re test, population, diagnosis, or comparison
299 Viedma JA, Garrigos N, Morales S. Comparison of the sensitivity of 2 automated immunoassays with immunofixation electrophoresis for detecting urine Bence Jones proteins. Clin Chem. Aug. 2005;51(8):1505-07. [pmid: 16040842]. Not relevant re test, population, diagnosis, or comparison
300 Wang H, Gao C, Xu L, et al. Laboratory characterizations on 2007 cases of monoclonal gammopathies in East China. Cellular & Molecular Immunology. Aug. 2008;5(4):293-98. [pmid: 18761817]. Not relevant re test, population, diagnosis, or comparison
301 Wechalekar AD, Lachmann HJ, Goodman HJ, et al. AL amyloidosis associated with IgM paraproteinemia: clinical profile and treatment outcome. Blood. Nov. 15. 2008;112(10):4009-16. [pmid: 18708629]. Not relevant re test, population, diagnosis, or comparison
302 Weiss BM, Abadie J, Verma P, et al. A monoclonal gammopathy precedes multiple myeloma in most patients. Blood. May. 28. 2009;113(22):5418-22. [pmid: 19234139]. Not relevant re test, population, diagnosis, or comparison
303 Weiss BM, Minter A, Abadie J, et al. Patterns of monoclonal immunoglobulins and serum free light chains are significantly different in black compared to white monoclonal gammopathy of undetermined significance (MGUS) patients. American Journal of Hematology. Jun. 2011;86(6):475-78. [pmid: 21544856]. Not relevant re test, population, diagnosis, or comparison
304 Wolff F, Thiry C, Willems D. Assessment of the analytical performance and the sensitivity of serum free light chains immunoassay in patients with monoclonal gammopathy. Clinical Biochemistry. Mar. 2007;40(5-6):351-54. [pmid: 17239359]. Not relevant re test, population, diagnosis, or comparison
305 Wood PB, McElroy YG, Stone MJ. Comparison of serum immunofixation electrophoresis and free light chain assays in the detection of monoclonal gammopathies. Clinical lymphoma, myeloma & leukemia. Aug. 1. 2010;10(4):278-80. Not relevant re test, population, diagnosis, or comparison
306 Xu JL, Davis MM. Diversity in the CDR3 region of V(H) is sufficient for most antibody specificities. Immunity. Jul. 2000;13(1):37-45. [pmid: 10933393]. Not relevant re test, population, diagnosis, or comparison
307 Yang CY. Using a heavy chain-loss hybridoma 26.4.1LL for studying the structural basis of immunoglobulin chain association. Proceedings of the National Science Council, Republic of China - Part B, Life Sciences. Jul. 2000;24(3):101-07. Not relevant re test, population, diagnosis, or comparison
308 Yegin ZA, Ozkurt ZN, Yagci M. Free light chain: a novel predictor of adverse outcome in chronic lymphocytic leukemia. European Journal of Haematology. May. 2010;84(5):406-11. [pmid: 20059535]. Not relevant re test, population, diagnosis, or comparison
309 Yoshida T, Matsuda M, Katoh N, et al. Long-term follow-up of plasma cells in bone marrow and serum free light chains in primary systemic AL amyloidosis. Internal Medicine. 2008;47(20):1783-90. [pmid: 18854629]. Not relevant re test, population, diagnosis, or comparison
310 Zingone A, Kuehl WM. Pathogenesis of monoclonal gammopathy of undetermined significance and progression to multiple myeloma. Seminars in Hematology. Jan. 2011;48(1):4-12. [pmid: 21232653]. Narrative review or commentary