# Acronyms

AACC: American Association for Clinical Chemistry
AHRQ: Agency for Healthcare Research and Quality
AL amyloidosis: Systemic, or primary, amyloidosis in which amyloid [A] proteins derived from immunoglobulin light chains [L] are deposited in tissue (also called light chain amyloidosis)
CER: Comparative Effectiveness Review
CI: Confidence interval
EBMT: European Group for Blood and Bone Marrow Transplant
ECOG: Eastern Cooperative Oncology Group
EPC: Evidence-based Practice Center
FDA: Food and Drug Administration
FLC: Free light chain
IFE: Immunofixation electrophoresis
IMWG: International Myeloma Working Group
ISS: International Staging System
LCMM: Light chain multiple myeloma
MGUS: Monoclonal gammopathy of undetermined significance
MM: Multiple myeloma
M protein: Monoclonal protein (also called paraprotein)
NSMM: Nonsecretory multiple myeloma
PCD: Plasma-cell dyscrasia
KQ: Key Question
PICO (also PICOTS): Populations, interventions (diagnostic tests/disease monitoring), comparators, outcomes (and timing and settings)
SCT: Stem-cell transplantation
SFLC: Serum free light chain
SIFE: Serum immunofixation electrophoresis
SPEP: Serum protein electrophoresis
TEP: Technical Expert Panel
TOO: Task Order Officer
UIFE: Urine immunofixation electrophoresis
UPEP: Urine protein electrophoresis
VDD: Bortezomib, pegylated liposomal doxorubicin, and dexamethasone
VGPR: Very good partial response