# Results

Our bibliographic database searches, conducted through January of 2012, identified 1,681 unique references.

- Triage of titles and abstracts identified 170 references meriting comprehensive screening. Backward citation searches of relevant systematic reviews identified an additional 12 references, for a total of 182 for screening. Figure 3 describes the literature search and screening process. Full text screening identified 16 unique studies meeting inclusion criteria. The most common reason for exclusion was the lack of a comparison group (59 studies). Other common reasons for exclusion included no intervention, no primary or secondary outcome, ineligible study design, and sample comprised of less than 75 percent moderate to severe TBI survivors. A complete listing of excluded studies appears in Appendix C.

Figure 3 Literature flow diagram

Figure 3 is the literature flow diagram. It describes the search and screen processes which is also described in the report text.

All studies assessed a prespecified primary outcome or a secondary outcome determined a priori or during the screening process as described in this report’s Methods section. We identified eight scales that we categorized as patient-centered secondary outcomes because they reflected or incorporated broader outcomes relative to participation, quality of life, or functioning in a community setting.

Table 5 provides an overview of eligible studies listing the primary and secondary outcomes assessed. The overall risk of bias assessments are also documented in Table 5. All studies were used to answer KQ1, but only studies with a low or moderate risk of bias were used to answer KQ2–5. Details describing these assessments are provided in Appendix B, Table 1.

Table 5 Overview of included studies

Study | Study design | Productivity | Community Integration Questionnaire (CIQ) | Mayo-Portland Adaptability Inventory (MPAI-4) | Craig Handicap Assessment and Reporting technique Short form (CHART-SF) | Secondary Patient-Centered Outcome | Overall Risk of Bias Assessment
Cicerone 2008^70^ | RCT | ✓ | ✓ | | | PQoL | Moderate
Vanderploeg 2008^71^ | RCT | ✓ | | | | DRS | Low
Salazar 2000^72^ | RCT | ✓ | | | | | Moderate
Greenwood 1994^73^ | RCT | ✓ | | | | DRS, GOS-E | Moderate
Ponsford 2006^74^ | Cohort | ✓ | | ✓ | ✓ | | High
Sarajuuri 2005^76^ | Cohort | ✓ | | | | | Moderate
Prigatano 1994^78^ | Cohort | ✓ | | | | | High
Rattok 1992^79^ | Cohort | ✓ | | | | | Moderate
Prigatano 1984^77^ | Cohort | ✓ | | | | | Moderate
Hashimoto 2006^75^ | Cohort | | ✓ | | | | High
Cicerone 2004^61^ | Cohort | | ✓ | | | QCI | Moderate
Willer 1999^80^ | Cohort | | ✓ | | | | High
Bell 2005^81^ | RCT | | | | | GOS-E, EuroQol, MPQoL | Moderate
Powell 2002^82^ | RCT | | | | | BICRO-39 | Moderate
Thomas 2004^83^ | Cohort | | | | | QOLI^®^ | High
Semlyen 1998^60^ | Cohort | | | | | NIAF-R | High
Total number of studies eligible | | 9 | 4 | 1 | 1 | 8
Less High Risk of Bias | | 2 | 2 | 1 | 1 | NA
Studies used to assess SOE | | 7 | 2 | 0 | 0 | NA

BICRO-39 = Brain Injury Community Rehabilitation Outcome scale; EuroQol = a quality-of-life instrumented developed by the EuroQol Group; GOS-E =Glasgow Outcome Score-Extended; MPQol =modified Perceived Quality of Life; NA = not applicable; NIAF-R = Newcastle Independence Assessment Form - Research; PQoL = Perceived Quality of Life; QOLI^®^ = Quality of Life Inventory; RCT = randomized controlled trial; SOE = strength of evidence. Note: This table lists the 16 studies meeting inclusion criteria. The primary and secondary patient-centered outcomes reported in those studies and the overall risk of bias assessment for studies assessing a primary outcome are also documented. The net number of studies for which SOE was assessed in evaluating effectiveness Key Questions is described.

## Previous Systematic Reviews

We identified several relevant systematic reviews with Key Questions, included populations or outcomes that differed from ours; thus we considered them partially relevant and used them in a limited fashion. We reviewed their lists of included studies for eligibility in this review. In the Discussion section of this report, we compare our conclusions with those of other reviews.

## Description of Eligible Studies

Evidence tables describing the studies appear in Appendix E, Table E-1. Four RCTs and eight cohort studies addressed primary outcomes. Cicerone et al. conducted two studies, a prospective cohort study61 and an RCT,70 to assess the effectiveness of an intensive cognitive rehabilitation program (ICRP) as compared to standard treatment in chronically impaired moderate to severe TBI survivors. Vanderploeg et al. conducted an RCT comparing two intensive impatient rehabilitation approaches for veterans or active duty military personnel with moderate to severe TBI.71 Salazar et al. conducted an RCT to assess the comparative effectiveness of an intensive inpatient cognitive rehabilitation program to a limited home-based rehabilitation program.72 Greenwood et al. conducted an RCT by randomizing hospitals to complement existing rehabilitation services with case management and compared results to the group of hospitals not adding the service.73 Ponsford et al. compared a cohort participating in a community-based postacute rehabilitation program to a group of patients participating in the center-based program it replaced.74 Hashimoto et al. compared patients in a day treatment program to controls not participating in the program.75 Sarajuuri et al. compared a cohort of moderate to severe TBI survivors enrolled in an intensive inpatient program to those receiving standard care.76 Prigatano et al. conducted two cohort studies comparing neuropsychological rehabilitation to nonparticipants.77, 78 Rattock et al. studied three treatment mixes for comparative effectiveness.79 Willer et al. evaluated the comparative effectiveness of a residential rehabilitation program to standard care.80

Four studies assessed only secondary outcomes, two RCTs and two cohort studies. Bell et al. conducted an RCT to evaluate the comparative effectiveness of a telephone counseling and education program to the standard program without the additional service.81 Powell conducted an RCT to compare an outreach program to an information-only intervention.82 Thomas evaluated the effectiveness of an outdoor experiential education program adapted to TBI survivors with chronic impairments as compared to patients that did not enroll in the program.83 Semlyen et al. compared the effectiveness of a coordinated multidisciplinary program provided at a regional rehabilitation center to care provided by other facilities.60

## Key Question 1 How have studies characterized multidisciplinary postacute rehabilitation for TBI in adults?

### Key Points

Studies of multidisciplinary postacute rehabilitation for moderate to severe TBI in adults do not always adequately define intervention and control treatments.

Multidisciplinary postacute rehabilitation is delivered in a variety of settings, including inpatient and outpatient rehabilitation centers, community- and home-based settings.

Most interventions do not appear to be theoretically based. However, references to certain models of care are frequently reported. Multidisciplinary rehabilitation programs based on models of care described by Ben-Yishay, Prigatano, and others are the most frequently studied.

Studies rarely report efforts that demonstrate effective implementation of interventions, such as the availability of manuals or other documentation outlining the interventions, staff training, and/or fidelity checks.

### Detailed Analysis

All 16 eligible studies were used to characterize interventions. Many studies did not provide detailed definitions of examined interventions. Definitions appeared to improve over time, with more recent studies providing more detailed definitions. Table 6 describes characteristics of studied interventions and Appendix E, Table E-2 provides the intervention definition data extractions. Despite the lack of a consistent taxonomy, interventions could be grouped on several levels. Interventions differed by target populations for which the interventions were designed; setting in which intervention took place; the models of care used to develop the intervention; how the intervention was delivered; and intervention intensity and duration.

Table 6 Characteristics of studied interventions

Study location | Target Population | Intervention Studied | Model of Care | Setting | Delivery | Intensity Duration | Total Therapy Hours
Bell 2005^81^ United States | Early Postacute through Chronic Moderate to Severe | Telephone counseling | | Home (telephone) | Individuals | 30–45 min/wk 9 mos | 18–27 (incremental)
Cicerone 2004^61^, 2008^70^ United States | Chronic Moderate to Severe | Intensive Cognitive Rehabilitation Program | Holistic Day Treatment | Outpatient rehabilitation center | Small groups | 15 hrs/wk 16 wks | 240
Greenwood 1994^73^ UK | Early Postacute through Chronic Severe | Case management | | Home | Individuals | NR | NR
Hashimoto 2006^75^ Japan | Chronic Moderate to Severe | Comprehensive Day Treatment Program | Holistic Day Treatment | Outpatient rehabilitation center | Small groups | 8–16 hrs/wk 3–6 mos | 96–144
Pondsford 2006^74^ Australia | Postacute Moderate to Severe | Community-based therapy program | NR | Community | Individuals | NR | NR
Pondsford 2006^74^ Australia | | Hospital-based outpatient treatment | NR | Outpatient rehabilitation center | Individuals | NR | NR
Powell 2002^82^ UK | Chronic Severe | Outreach | NR | Home or community | Individuals | 2–6 hrs/wk 27 wks (mean) | NR
Powell 2002^82^ UK | | Information | NR | Home | Individuals | 1 hr 1 session | 1
Prigatano 1984^77^, 1994^78^ United States | Chronic Moderate to Severe | Neuropsychological rehabilitation | Holistic Day Treatment | Outpatient rehabilitation center | Small groups | 24 hrs/wk 6 mos | 576
Rattok 1992^79^ United States | Chronic Moderate to Severe | Treatment Mix 1 (balanced) | Holistic Day Treatment | Outpatient rehabilitation center | Small groups | 5 hrs/wk 4 wks | 200
Rattok 1992^79^ United States | | Treatment Mix 2 (interpersonal) | Holistic Day Treatment | Outpatient rehabilitation center | Small groups | 5 hrs/wk 4 wks | 200
Rattok 1992^79^ United States | | Treatment Mix 3 (cognitive) | Holistic Day Treatment | Outpatient rehabilitation center | Small groups | 5 hrs/wk 4 wks | 200
Salazar 2000^72^ United States | Active duty military Early postacute Moderate to severe Mild impairments | Inpatient Cognitive Rehabilitation | Holistic Day Treatment | Inpatient | Small groups | NR 6 wks | NR
Salazar 2000^72^ United States | Active duty military Early postacute Moderate to severe Mild impairments | Home rehabilitation | NR- | Home | Individuals | .5 hr/wk 8 wks; | 4
Sarajuuri 2005^76^ Finland | Chronic Moderate to Severe | Comprehensive neurorehabilitation | Holistic Day Treatment | Inpatient | Small groups | 37.5 hrs/wk 6 wks | 225
Semlyen 1998^60^ UK | Early postacute Severe | Multidisciplinary rehabilitation | NR | Combination Inpatient/outpatient rehabilitation center | Individuals | NR | NR
Thomas 2004^83^ Tasmania | Chronic Moderate to Severe | Outdoor Experiential Education | Outward Bound | Camp-like setting Community | Small groups | OEE – 9 wks Follow-up groups – 3–4 mos. | NR
Vanderploeg 2008^71^ United States | Active-duty military, veterans Early postacute Moderate to Severe | Cognitive didactic | Cognitive-didactic | Inpatient | Individuals | 7.5–15 hrs/wk 32 days (mean) | NR
Vanderploeg 2008^71^ United States | | Functional-experiential | Functional treatment concepts | Inpatient | Small groups | 21.5–30 hrs/wk 33 days (mean) | NR
Willer 1999^80^ United States | Chronic Severe Multiple disabilities | Community-based residential rehabilitation | Cognitive rehabilitation and community adaptation | Residential | Individuals | NR 1–3 yrs | NR

Note: This table briefly describes characteristics of the studied interventions.

Studies focused on evaluating new models of care, comparing different models of care, or assessing particular components added to a standard program. Four studies assessed certain rehabilitation programs and compared results to those not participating in the program.61, 75, 77, 78, 83 Six studies compared new models of care delivered by their institution or agency to a standard care typically delivered to that community.60, 61, 70, 74, 76, 80 Five studies compared different models of care where the interventions varied by setting, intensity, or approach.71, 72, 79, 82 Two studies examined an additional component added to a standard program.73, 81

Most of the programs studied were geared towards TBI survivors whose impairments were chronic or had lasted on average more than 6 months postinjury. However, three interventions addressed patients earlier in the postacute period.60, 71, 72 Two interventions began earlier in the postacute period and continued to the chronic stage.73, 81 Other programs specifically addressed survivors of severe injuries60, 73, 80 or military populations.71, 72

Programs typically engaged a similar variety of disciplines. Eight programs described programs based upon models of care originally described by Ben-Yishay, Prigatano, and others.61, 70, 72, 75–79 These programs have been called “comprehensive holistic day treatment,” and the interventions emphasized cognitive rehabilitation and an integrated approach. They also included therapies delivered in a similar manner, in which small groups of five to eight participants progressed through rehabilitation together. These programs typically involved substantial group therapy when compared to standard rehabilitation programs. A variety of therapy types were provided, with vocational rehabilitation as a core component. Most were day-treatment programs in outpatient rehabilitation centers, but two were residential treatment programs.72, 76 A single program citing this model of care addressed TBI survivors in the early postacute period, within 3 months from injury.72 Despite their many similarities, interventions based upon this model varied in duration of treatment from 6 weeks to 6 months.

Other programs described outreach to TBI survivors;82 community-based care;74 specific approaches to remediation of skills;71 multidisciplinary programs without mentioning a specific model;60 residential communities of TBI survivors;80 and an outdoor experiential education program.83 Specific components of programs that were studied included case management73 and telephone counseling.81

#### Program Characteristics

Several postacute multidisciplinary rehabilitation programs were studied.60, 61, 70–72, 74–80, 82, 83 Three programs compared the effectiveness of programs delivered to TBI survivors earlier in the postacute period.60, 71, 72

Vanderploeg et al. compared two inpatient approaches to rehabilitate TBI survivors within 6 months of injury71. In addition to daily occupational and physical therapy, study participants received 1.5 to 2.5 hours per day of either cognitive-didactic treatment or functional-experiential therapy. The cognitive-didactic approach targeted four cognitive domains; practiced trial and error in performing exercises; emphasized self-awareness; and aimed to directly rehabilitate the cognitive deficits that underlie functional deficits after TBI, a restorative approach. Cognitive-didactic treatments were delivered to participants on an individual basis. The functional-experiential approach used real-life situations to remediate or compensate for the functional deficits. Treatments were delivered in group settings; with an errorless learning strategy; and with an emphasis on repetition to rebuild functional status.

Salazar et al. compared two rehabilitation programs delivered in different settings targeted to relatively mildly impaired survivors of moderate to severe TBI within 3 months of injury.72 The 8-week inpatient treatment consisted of interdisciplinary cognitive rehabilitation combining group and individual therapies. This program was based on a model of care previously described by Prigatano and others. The program was structured and involved group and individual cognitive, speech, occupational, and coping skills therapies, and vocational rehabilitation. Participants in the home rehabilitation program received 30 minutes of weekly telephone counseling and education from a psychiatric nurse. They also received educational materials and advice about strategies for enhancing cognitive and organizational skills.

Semlyen et al. described a coordinated, multidisciplinary rehabilitation service provided by the local rehabilitation center.60 Combined inpatient and outpatient services were delivered on an individual basis as determined by patient needs. Patient goals were established and reviewed weekly in concert with the care team.

Programs based on the comprehensive holistic model (except as studied by Salazar et al.)72 addressed chronic impairments of moderate to severe TBI.61, 70, 75–79 Of these, all but one76 were outpatient day-treatment programs.

Cicerone and colleagues conducted two studies to assess the comparative effectiveness of the ICRP, an alternative model of comprehensive day treatment implemented at a postacute brain injury rehabilitation center.61, 70 This structured, intensive 16-week group intervention provided 15 hours of combined individual and group therapies, 3 days per week. The program emphasized integration of interventions for impairments across domains, and treatments focused on compensatory approaches to address chronic limitations. Groups of five to eight participants progressed together through the program, which utilized extensive group sessions supplemented with a lesser number of individual sessions.

Prigatano et al. also evaluated this model in two separate studies.77, 78 Characteristics of their program suggested an intensive and coordinated approach. Groups progressed through the program and participated in four sessions per week, 6 hours per day, for 6 months. Group and individual therapy sessions emphasized self-awareness, acceptance of residual impairments retraining, and compensatory approaches to cognitive deficits.77 The later study described a similar intervention called a “work re-entry program,” composed of interdisciplinary therapies. Small groups participated in therapies 4 to 5 mornings per week for 6 months. Sessions taught patients to participate responsibly as members of small communities, stressing social integration and simulated community situations. After 6 to 8 weeks in the program, participants devoted afternoons to protected work trials of 15 to 20 hours per week.

Hashimoto et al. implemented variations of programs based on the comprehensive holistic model of care.75 Their program varied in intensity and duration, but maintained the same basic approach. Social skills training based on the positive behaviorist support program was a key component.

Rattock et al. studied three treatment mixes in a program delivered to chronically impaired TBI survivors.79 All contained training to alleviate attention disorders, therapeutic recreation, and individual counseling. The first treatment mix was a balanced approach that supplemented the above components with cognitive remediation and small group social skills training. The second treatment mix emphasized the social skills training without cognitive remediation. The third treatment mix emphasized individual cognitive skills training without social skills training.

Sarajuuri et al. studied a program based upon the comprehensive holistic day-treatment model of care, targeting chronic impairments from moderate to severe TBI.76 This 6-week inpatient program (called INSURE) was conducted in Finland for select groups of patients with TBI. Groups of five to eight patients received 7.5 hours daily of neuropsychological rehabilitation core therapies, with individual therapies incorporated as needed. The INSURE program emphasized the therapeutic alliance between the patient and the care team, and consisted of goal setting; group and individual psychotherapy; group cognitive sessions emphasizing compensatory approaches; group speech and language coaching; and, finally, group sessions focused on self-awareness, quality of life, and therapeutic recreation.

Other examined programs reflected additional models or theories. Thomas evaluated an outdoor experiential education program adapted to brain injury survivors with chronic impairments.83 The author cited a theoretical model describing four tasks of adjustment to brain injury as the underpinning for the intervention. The program was developed through a partnership between a local brain injury service and Outward Bound Australia. The program had three stages; the first focused on raising funds for participation in the program, and clarification of program objectives. The second stage was the 9-day Outward Bound “Discovery” course, adapted for this population from the traditional course, and based on a range of challenging outdoor activities. Participants were encouraged to accept increasing responsibility and attend to activities of daily living in a basic camping environment. The 3- to 4-month followup phase (after returning from the outdoor program) consisted of regular group work. The continued group sessions were intended to help participants use the insights and gains from the outdoor program to achieve personal goals. Key focus areas included social skills, vocational training, and increased independence. Rehabilitation staff members facilitated the groups with the goal of restructuring tasks through activities.

The remaining studies did not report being based on specific models of care or describe the theories on which their programs were based.74, 80, 82 Ponsford et al. evaluated a program change from center-based outpatient rehabilitation to community-based services.74 The community-based program conducted assessments and therapies in the home, workplace, or other relevant community setting. Specific goals and therapeutic interventions were planned based on assessment and discussion with patients and families. Treatment was provided by a variety of professionals, with each specific therapy offered once a week or less. Sessions also involved training for all caretakers involved in the rehabilitation process.

Powell et al. compared two approaches rehabilitation for chronically impaired TBI survivors.82 The more intensive outreach program offered 2 to 6 weekly hours of individualized treatments in patients’ homes or other community settings. Interventions were based on initial assessments and identified treatment goals. The less intensive program involved information only, with one home visit from a team therapist and the provision of an informational booklet highlighting resources in the community of potential benefit to the patient.

Willer et al. studied a residential postacute rehabilitation program providing a broad range of services.80 Treatments were coordinated by a neuropsychologist, with specific therapies designed to meet each patient’s needs. After extensive training, paraprofessionals delivered treatments and served as role models for social skills. All support staff were trained in issues relevant to TBI impairments and rehabilitation.

Two studies evaluated a single component of comprehensive rehabilitation programs.73, 81 Both of these programs offered services beginning earlier in the postacute period that continued through the chronic period of recovery. Bell et al, studied a telephone intervention.81 First contact with the TBI survivor or a caregiver occurred within 2 weeks of discharge from inpatient rehabilitation. Subsequent contact occurred at 4 weeks, and at 2, 3, 5, 7, and 9 months. Calls were scheduled to last between 30 and 45 minutes. Each telephone contact contained three basic elements: (1) a followup to concerns raised on the previous call; (2) identification of current concerns; and (3) the recommended intervention in response to current concerns. Calls were supplemented with informational mailings as determined relevant. Staff providing the phone counseling were trained in principles of motivational interviewing. Greenwood et al. studied a case management program added to standard rehabilitation services.73 The case management intervention involved the formulation of a detailed rehabilitation plan, and the facilitation of cooperation from appropriate professionals to implement the plan. No formal professional services were provided by case managers.

#### Implementation of Multidisciplinary Rehabilitation Treatments

Adequately implementing the interventions is as important as adequately describing them. Few studies reported implementation efforts such as the availability of manuals defining treatments, staff training, and fidelity or adherence checks. Few studies reported a manual or other detailed documentation with thorough intervention content.72, 76, 77, 83 Two studies reported staff training prior to beginning of the study.71, 80 Two studies described efforts to ensure fidelity to treatment protocol.70, 71

## Key Question 2 What is the effectiveness and comparative effectiveness of multidisciplinary postacute rehabilitation for TBI?

a. Do effectiveness and comparative effectiveness vary by rehabilitation timing, setting, intensity, duration, or composition?
b. Do effectiveness and comparative effectiveness vary by injury characteristics?
c. Do effectiveness and comparative effectiveness vary by patient characteristics, preinjury or postinjury?

### Key Points

Table 7 summarizes the populations, interventions, outcomes, timing of outcome measurement, and direction of effect for all primary outcomes studies.

Table 7 Overview of primary outcomes with strength of evidence

Treatments; Study Design | Study Populations | Outcome Definition | Post-Treatment Assessment | Followup post-Treatment Assessment
Intensive cognitive rehabilitation versus Standard neurorehabilitation Study 1 RCT70 Study 2 non-RCT61 | Study 1: 68 American TBI patients (mild 13%), at least 3 months post-injury, in a post-acute brain injury rehabilitation center within a suburban rehabilitation hospital. Mean age 37, Male 68%. Study 2: 57 American TBI patients (mild ~10%) in community-based, post-acute outpatient brain injury rehabilitation program Mean age 37, Male 71%. | Engaged in community-based employment | ↑↑ 16 weeks (Study 1) Low strength of evidence (SOE) | ↔ 6 months (Study 1) Low SOE
Intensive cognitive rehabilitation versus Standard neurorehabilitation Study 1 RCT70 Study 2 non-RCT61 | | Community Integration Questionnaire | ↔ 16 weeks (Study 1 and Study 2) Low SOE | ↔ 6 months (Study 1) Low SOE
Functional-experiential versus Cognitive-didactic71 RCT | 360 American Veterans Affairs inpatients (active duty or veteran) with non-penetrating TBI within the preceding 6 months. Mean age 32, Male >90%. | Paid employment or school enrollment, either full or part time | not reported | ↔ 1 year (n=331)^a^ Low SOE
Hospital treatment versus Home treatment72 RCT | 120 American active duty military patients with a closed head injury within 3 months of randomization. All subjects had a Rancho Los Amigos cognitive level of 7 (oriented, appropriate). Mean age 25, Male >90% | Gainful military or civilian employment, either full or part time | not reported | ↔ 1 year Low SOE
Case management Versus Conventional rehabilitation 73 RCT (hospitals, not patients) | 126 British TBI patients with closed head injury. Case-managed patients were more severely injured at study entry (Glasgow coma score and amnesia P<0.05 between groups). Mean age 31, Male 73% | At competitive work | ↔ 6 months (n=95) Insufficient SOE | ↔ 1 year (n=77) Insufficient SOE ↔ 2 years (n=46) Insufficient SOE
Comprehensive neurorehabilitation (INSURE) versus Conventional rehabilitation76 Non-RCT | 39 Finnish TBI patients who were independent in daily life and had only slight physical disabilities. Comprehensive neurorehabilitation was in an inpatient setting. Mean age 30, Male 85% | Working, studying, or participating in volunteer activities | not reported | ↑ 2 years Insufficient SOE
Neuropyschological rehabilitation versus Controls77 Non-RCT | 35 American closed head injury outpatients in a neuropsychological rehabilitation program compared to similar head injury controls. Mean age 25, Male 86% | Gainfully employed or actively engaged in a realistic school program | not reported | ↔ Unclear, following 6 months treatment (n=32) Insufficient SOE
Treatment Mix 1 (balanced package, including cognitive remediation and small group interpersonal communication training) versus Treatment Mix 2 (similar to Mix 1 stressing small group inter-personal communication training but without cognitive remediation) versus Treatment Mix 3 (emphasis on individualized cognitive remediation but without small group interpersonal communication training)79 Non-RCT | 59 American TBI (open or closed) patients that had been discharged from inpatient rehabilitation and had been living at home with relatives. In most cases, traditional methods of rehabilitation had failed to stabilize patients in terms of their personal and social adjustments and their return to work. Mean age 27, Male 71% | Productive employment | not reported | ↔ 9 months Insufficient SOE

↑↑ Moderate or greater effect (statistically significant) between treatment arms (Relative risk >2.0 or effect size >0.5)

↑ Small effect (statistically significant) between treatment arms (Relative risk <2.0 or effect size <0.5)

↔ No statistically significant differences between treatment arms

a Number of patients evaluated reported here if different from baseline

Note: This table describes primary outcomes and strength of evidence with the populations and interventions to which they apply.

One small cohort study compared treatment to no treatment, and provided insufficient evidence to determine whether neuropsychological rehabilitation for impairments from moderate to severe TBI was effective at improving return to work at 6 to 24 months post-treatment.

A low strength of evidence demonstrated that the cognitive-didactic approach was no more effective than functional-experiential approach during the early postacute phase in achieving productivity outcomes 1-year post-treatment in a military and veteran population with moderate to severe closed head injuries.

A low strength of evidence demonstrated that a 6-week inpatient postacute rehabilitation program was no more effective than limited home-based rehabilitation during the early postacute period in achieving productivity outcomes 1-year post-treatment in a military population.

A low strength of evidence demonstrated that the ICRP during the chronic phase was more effective than standard rehabilitation at improving productivity outcomes, but not community integration outcomes, immediately post-treatment in a civilian population. However, group differences were no longer significant at 6 months post-treatment.

### Detailed Analysis

Of the 16 studies eligible studies, 13 assessed primary outcomes and eight assessed secondary outcomes. Nine of the primary outcomes studies assessed productivity or employment (four RCTs, five cohort studies). Two of the cohort studies were evaluated to have a high risk of bias and thus excluded from analysis.74, 78 One cohort study assessed MPAI-3 and the CHART-SF. However, this study was evaluated as having a high risk of bias,74 leaving no eligible studies using either the MPAI or the CHART-SF. Four studies assessed effectiveness with the CIQ (one RCT and three cohort studies). Two of the cohort studies were evaluated as having a high risk of bias and excluded,75, 80 leaving two studies for analysis (one RCT and one cohort study).61, 70 Of the eight studies used to analyze primary outcomes, one was rated low risk of bias,71 and eight were rated moderate risk of bias61, 70, 72, 73, 76, 77, 79 for respective outcomes.

The eight studies were heterogeneous in terms of populations, interventions, controls, and outcomes definition and measurement. Study characteristics are summarized in Table 8. Sample sizes ranged from 36 to 366. Six studies were conducted in the United States,61, 70–72, 77, 79 one in the United Kingdom,73 and one in Finland.76 Subjects were predominantly male (85 percent) and young relative to the adult population of the United States (mean age of 31). Studies rarely reported other demographic statistics. Median time since injury varied widely among studies, from 1 to 45 months with a median of 19 months. Two studies specifically restricted enrollees to those within 3^72^ or 6^71^ months of injury while another restricted enrollment to individuals at least 3 months postinjury.70 Several studies included participants with a wide range of time since injury. For instance, the Cicerone RCT included participants with injuries from 3 months to over 5 years prior to enrollment.

Table 8 Summary of study population characteristics (primary outcome studies with low of moderate risk of bias)

Characteristic | Mean (Range) Unless Otherwise Noted | Number of Studies Reporting
Total number of patients evaluated | 870 (36 to 366) | 8
Randomized trials, number of patients | 680 (49 to 366) | 4 a,b,c,h
Nonrandomized studies, number of patients | 190 (36 to 59) | 4 d,e,f,h
Age of subjects, years | 31 (25 to 38) | 8
Sex, male, % of patients | 85 (68 to 94) | 8
White race/ethnicity, % of patients | 70 (69 to 75) | 3 a,b,c
Married, % of patients | 28 (25 to 35) | 3 a,b,c
Education, years | 13 (12 to 13) | 4 a,e,f,^g^
Education, high school or greater, % of patients | 94 | 1 b
Education, some college or greater, % of patients | 42 | 1 c
Employment status, preinjury | 91 (81 to 100) | 7 a,b,c,d,e,f,h
TBI Severity, % mild (studies that included patients with minor TBI) | 12 (11 to 13) | 2 a,e *
Time postinjury (months) | 12 (1.3 to 45) | 7 a,b,c,d,e,f
Time postinjury (months), median | 19 (1.3 to 45) | 7
TBI etiology-motor vehicle accident, % of patients | 63 (38 to 67) | 4 b,c,d,h
TBI etiology-assault, % of patients | 11 (5 to 19) | 4 b,c,d,h
TBI etiology-fall, % of patients | 15 | 2 b,h **
History of psychiatric illness/treatment, % of patients | 19 (13 to 22) | 2 a,c
History of alcohol and/or substance abuse, % of patients | 31 (21 to 37) | 2 a,c
Studies done in the United States, number of patients | 705 (36 to 366) | 7 a,b,c,e,f,^g^
Studies done outside the United States, number of patients | 165 | 2 d,h,†

a Cicerone 2008;

b Vanderploeg 2008;

c Salazar 2000;

d Sarajuuri 2005;

e Cicerone 2004;

f Prigatano 1983;

h Rattok 2004;

i Greenwood 1994

* The remaining 4 studies included participants with only moderate to severe TBI.

** Sarajuuri 2005 combined fall and blunt object injury (33% of TBI).

† Finland and United Kingdom

Studies rarely reported functional status at time of enrollment, either as an inclusion criterion or as a baseline characteristic. The Salazar RCT restricted enrollment to those with Rancho Los Amigos cognitive level of 7.^72^ Other studies reported inclusion criteria suggesting that participants had been judged to need the level of treatment administered in the study,70, 71 suggesting some threshold level of impairment. Other studies enrolled participants judged to have adequate potential to achieve productivity76 or who had been unsuccessful in other rehabilitation programs.79

Primary studies typically failed to report many other variables believed to be related to recovery and rehabilitation response, such as measures of social support, comorbidities, concomitant treatments, prior employment, and compensation seeking status.

Methods of collecting outcome data also varied. Cicerone collected CIQ data self-reported by participants under supervision.70 Other primary outcomes data were described as being obtained through interview, military records, or both,72 and through structured interview questions.71

#### Productivity

Productivity outcomes are presented in Table 9. Overall strength of evidence and the individual strength of evidence component assessments for each outcome or comparison appear in Table 10. Because of the heterogeneity in comparisons across studies, SOE was assessed most often at the single study level. Only one eligible study assessing productivity compared the intervention to a no-treatment group. This small cohort study found no significant difference in the proportion gainfully employed at followup (50 percent versus 36 percent) at one timepoint somewhere between 6 and 24 months post-treatment. However, this study was likely underpowered and did not adequately control for confounding. Thus it provided insufficient evidence about effectiveness.

Table 9 Productivity outcomes

Study Design Outcome and Description | Treatment Arms | % Working or Productive (n/N) Before Treatment | % Working or Productive (n/N) After Completion of Treatment | Treatment Vs. Control at Endpoint
Cicerone 2008^70^ RCT Productive^a^ post-treatment (16 wks) | Intensive cognitive rehabilitation | 9% (3/34) | 47% (16/34) | RR: 2.29 [1.08 to 4.84] P=0.03
Cicerone 2008^70^ RCT Productive^a^ post-treatment (16 wks) | Standard neurorehabilitation | 12% (4/34) | 21% (7/34) | RR: 2.29 [1.08 to 4.84] P=0.03
Vanderploeg 2008^71^ RCT RTW^b^ at 1 yr post protocol treatment | Functional-experiential | NR | 35% (58/164) | RR: 0.91 [0.69 to 1.20] P=0.50
Vanderploeg 2008^71^ RCT RTW^b^ at 1 yr post protocol treatment | Cognitive-didactic | NR | 39% (65/167) | RR: 0.91 [0.69 to 1.20] P=0.50
Salazar 2000^72^ RCT RTW^c^ in 12 mos post-treatment | Hospital | NR | 90% (60/67) | RR: 0.95 [0.85 to 1.05] P=0.33
Salazar 2000^72^ RCT RTW^c^ in 12 mos post-treatment | Home | NR | 94% (50/53) | RR: 0.95 [0.85 to 1.05] P=0.33
Salazar 2000^72^ RCT Fitness for Duty in 12 mos post-treatment | Hospital | NR | 73% (49/67) | RR: 1.11 [0.87 to 1.41] P=0.41
Salazar 2000^72^ RCT Fitness for Duty in 12 mos post-treatment | Home | NR | 66% (35/53) | RR: 1.11 [0.87 to 1.41] P=0.41
Greenwood 1994^73^ RCT (Hospitals – not patients) At competitive work 6 mos post injury | Case management | 100% (42/42) | 24% (10/42) | RR: 0.84 [0.42 to 1.68] P=0.62
Greenwood 1994^73^ RCT (Hospitals – not patients) At competitive work 6 mos post injury | Conventional rehabilitation | 96% (54/56) | 28% (15/53) | RR: 0.84 [0.42 to 1.68] P=0.62
Sarajuuri 2005^76^ Prospective Cohort Productive^d^ 2 yrs post-treatment | Comprehensive neurorehabilitation | 5% (1/19) | 89% (17/19) | RR: 1.63 [1.06 to 2.49] P=0.02
Sarajuuri 2005^76^ Prospective Cohort Productive^d^ 2 yrs post-treatment | Conventional rehabilitation | NR | 55% (11/20) | RR: 1.63 [1.06 to 2.49] P=0.02
Rattok 1992^79^ Prospective Cohort Productive^e^ 9 mos post-treatment | Treatment Mix 1 (balanced package, including cognitive remediation and small group interpersonal communication training) | NR^f^ | 70% (16/23) | P=0.33 between all groups Treatment mix was unrelated to the number of patients attaining employment
Rattok 1992^79^ Prospective Cohort Productive^e^ 9 mos post-treatment | Treatment Mix 2 (similar to Mix 1 stressing small group inter-personal communication training but without cognitive remediation) | NR^f^ | 89% (16/18) | P=0.33 between all groups Treatment mix was unrelated to the number of patients attaining employment
Rattok 1992^79^ Prospective Cohort Productive^e^ 9 mos post-treatment | Treatment Mix 3 (emphasis on individualized cognitive remediation but without small group interpersonal communication training) | NR^f^ | 78% (14/18) | P=0.33 between all groups Treatment mix was unrelated to the number of patients attaining employment
Prigatano 1984^77^ Prospective Cohort RTW^g^ at followup (treatment was 6 mos) | Neuropsychological rehabilitation | NR | 50% (9/18) | P=0.49
Prigatano 1984^77^ Prospective Cohort RTW^g^ at followup (treatment was 6 mos) | Controls | NR | 36% (5/14)^h^ | P=0.49

RR = risk ratio [95 percent confidence intervals]

a according to Vocational Integration Scale dichotomized into productive (supported, transitional or competitive) vs. nonproductive (unemployed or sheltered employment)

b current status of paid employment or school enrollment, either full or part time, not sheltered workshop.

c Work defined working either FT (≥35 hours/week) or PT (≤35 hours/week) in gainful military or civilian employment.

d defined as working, studying, or participating in volunteer activities

e productive employment

f all subjects in the study had “unsuccessful vocational rehabilitation” prior to study entry

g defined as gainfully employed or actively engaged in a realistic school program at time of followup.

h 17 controls total but 3 were excluded (lost to followup)

Table 10 Strength of evidence for productivity outcomes

Intervention; Outcome | Comparison | Study Type | n | Summary Statistics RR [95% CI] | Risk of Bias | Directness | Precision | Consistency | Evidence Rating
Cicerone 2008^70^ Post-treatment, 16 weeks | Intensive cognitive rehabilitation vs. Standard neurorehabilitation | RCT | 68 | RR: 2.29 [1.08 to 4.84] | moderate^*^ | direct | precise | NA | Low
Vanderploeg 2008^71^ Post-treatment, 1 year | Functional-experiential vs. Cognitive-didactic | RCT | 331 | RR: 0.91 [0.69 to 1.20] | low | direct | imprecise | NA | Low
Salazar 2000^72^ Post-treatment, 1 year | Hospital-based therapy vs. Home-based therapy | RCT | 120 | RR: 0.95 [0.85 to 1.05] | moderate | direct | precise | NA | Low
Salazar 2000^72^ Post-treatment, 1 year | Hospital-based therapy vs. Home-based therapy | RCT | 120 | RR: 1.11 [0.87 to 1.41] | moderate | direct | imprecise | NA | Low
Greenwood, 1994^73^ Post-injury, 6 months | Case management vs. Conventional rehabilitation | RCT (Hospitals, not patients) | 126 | RR: 0.84 [0.42 to 1.68] | high | direct | imprecise | NA | Insufficient
Sarajuuri 2005^76^ Post-treatment, 2 years | Comprehensive neurorehabilitation vs. Conventional rehabilitation | , prospective cohort | 39 | RR: 1.63 [1.06 to 2.49] | high | direct | precise | NA | Insufficient
Rattok 1992^79^ Post-treatment, 9 months | Comparison of 3 “treatment mixes” | prospective cohort | 59 | - | high | direct | - | NA | Insufficient
Prigatano 1984^77^ Post-treatment, ranged from 6 mo to 2 years | Neuropsychological rehabilitation vs. Control (untreated) | Prospective cohort/retrospective control | 32 | RR: 1.40 [0.60 to 3.25] | high | direct | imprecise | NA | Insufficient

RR = risk ratio [95 percent confidence intervals]

* Moderate risk of bias indicates that the results are probably believable taking study limitations into consideration (low risk of bias would indicate that the results are believable taking study limitations into consideration and high risk of bias would indicate that the results are uncertain taking study limitations into consideration)

Note: This presents the assessment of the individual components of strength of evidence and the overall evidence rating. NA appears under consistency because only one study was available for each outcomes-comparison combination.

Six studies assessed the comparative effectiveness for productivity outcomes between groups participating in different interventions. Two larger RCTs found no productivity differences between groups of patients participating in different treatment programs early in the postacute period.71, 72 Vanderploeg et al. examined different approaches in four Veterans Affairs inpatient rehabilitation programs. A low strength of evidence demonstrated that the cognitive-didactic approach was no more effective than the functional-experiential approach during the earlier postacute phase in achieving productivity outcomes 1-year post-treatment in this military and veteran population with moderate to severe closed head injuries. Salazar et al. compared inpatient rehabilitation to home-based treatment.72 A low strength of evidence demonstrated that a 6-week inpatient postacute rehabilitation program was no more effective than limited home-based rehabilitation during the early postacute period in achieving productivity outcomes 1-year post-treatment in this military population. Generally, it is recommended that SOE be downgraded to insufficient in evaluating equivalent results between comparison groups if evidence is too imprecise.84 However, while this evidence in some cases is imprecise, we maintained our low SOE assessment because results were not grossly imprecise.

Cicerone et al. found that the group of chronically impaired civilians enrolled in the ICRP were significantly more productive immediately post-treatment than those who received standard treatment at that rehabilitation center (47 percent versus 21 percent).70 However, no group differences existed at followup 6-months post-treatment, by which time both groups had improved rates of productivity (60 percent versus 50 percent). In summary, we found a low level of evidence that the ICRP resulted in earlier productivity than a conventional program in chronically impaired moderate to severe TBI survivors judged to need 4 months of intensive treatment. However, the group difference no longer existed at 6 months post-treatment, because the control group had significantly improved their rates of productivity.

We found insufficient evidence to conclude whether the INSURE program was more or less effective than standard rehabilitation in improving participation 2 years post-treatment.76

We also found insufficient evidence to conclude whether case management added to conventional programs resulted in significantly different rates of productivity compared to conventional rehabilitation alone at various followup timepoints.73

#### Community Integration

Integration CIQ outcomes are presented in Table 11. Overall strength of evidence and individual component assessments for each comparison appear in Table 12. Neither of the two studies that evaluated community integration with the CIQ found significant group differences in CIQ scores post-treatment (ICRP = 12.9, standard rehabilitation = 11.7 in RCT;70 ICRP = 16.8, standard rehabilitation = 16.1, unadjusted in cohort study61). However, the authors suggest other indications of effectiveness. Specifically, a statistically significant improvement in the CIQ score for the ICRP group from baseline to the end of the program was reported in the RCT; however, mean differences between groups were not significantly different.61 The cohort study detected a greater rate of clinically meaningful change in the ICRP group (52 percent of the ICRP group showed clinically significant improvement of 4.2 points compared to 31 percent of the standard rehabilitation group). While these indications of potential benefit may have value, the data provided a low level of evidence that participation in ICRP versus standard rehabilitation achieved equivalent improvements in CIQ. We assessed the SOE low because it was derived from one moderately sized RCT with a moderate risk of bias. Results from the RCT were primarily used to assess SOE because the cohort study provided unadjusted results.

Table 11 Community integration questionnaire

Study Design Outcome Measurement | Treatment Arms | Score (SD), Before Treatment | Score (SD), After Completion of Treatment | Effect size (ES) [95%CI] for Treatment vs. Control; Comments
Cicerone 2008^70^ [underlined: RCT] Self report under supervision | Intensive Cognitive Rehabilitation Program (ICRP) (n=34) | 11.2 (3.4) | 12.9 (3.4) P<0.05 versus before treatment | ES=0.30 [−0.18 to 0.78] No significant differences between groups but Intensive cognitive rehabilitation participants showed greater improvements on the CIQ
Cicerone 2008^70^ [underlined: RCT] Self report under supervision | Standard Neurorehabilitation Program (STD) (n=34) | 12.1 (4.0) | 11.7 (4.4)
Cicerone 2004^61^ [underlined: Prospective Cohort] Administered and scored according to original procedures (Willer, 1993) | Intensive Cognitive Rehabilitation Program (ICRP) (n=27) | 11.6 (4.6) | 16.8 (4.2) ES vs. before treatment 1.16 [0.59 to 1.74] | ES=0.14 [−0.38 to 0.67] 52% of ICRP participants showed clinically significant improvement compared with 31% of SRP participants (OR=2.41 [0.8 to 7.2]
Cicerone 2004^61^ [underlined: Prospective Cohort] Administered and scored according to original procedures (Willer, 1993) | Standard Neurorehabilitation (SRP) (n=29) | 13.7 (4.4) | 16.1 (5.4) ES vs. before treatment 0.48 [−0.04 to 1.00] | The ICRP group exhibited over twice the magnitude of treatment effect on total CIQ than the participants receiving SRP (1.20 vs. 0.49).

OR = Odds ratio [95% confidence interval]

Table 12 Strength of evidence for the primary TBI studies: CIQ

Intervention; Assessment | Treatment Arms | Study Type | n | Summary Statistics [95% CI] | Risk of Bias | Directness | Precision | Consistency | Evidence Rating
Cicerone 2008^70^ Post treatment, 16 weeks | Intensive cognitive rehabilitation vs. Standard neurorehabilitation | RCT | 68 | ES = 0.30 [−0.18 to 0.78] | moderate^**^ | direct | imprecise | NA | Low
Cicerone 2004^61^ Post treatment, 16 weeks | Intensive cognitive rehabilitation vs. Standard neurorehabilitation | Prospective Cohort | 56 | OR = 2.41 [0.8 to 7.2]^†^ | high | direct | imprecise | NA | Insufficient

* ES = effect size (standardized mean difference), calculated by using Hedges’ adjusted g,

** Medium risk of bias indicates that the results are probably believable taking study limitations into consideration (low risk of bias would indicate that the results are believable taking study limitations into consideration and high risk of bias would indicate that the results are uncertain taking study limitations into consideration)

† OR = odds ratio, participants achieving clinically significant improvement, treatment versus control.

#### Secondary Outcomes

Table 13 summarizes findings for secondary outcomes in all eligible studies with a risk of bias assessment of low or moderate. Six studies assessed six measures considered secondary patient-centered outcomes.

Table 13 Overview of secondary outcomes results

Treatments; Study Design | Study Populations | Outcome Definition | Post-Treatment Assessment | Followup Post-Treatment Assessment
Intensive cognitive rehabilitation vs. Standard neurorehabilitation70 RCT | 68 American TBI patients (mild 13%), at least 3 months post-injury in a postacute brain injury rehabilitation center within a suburban rehabilitation hospital. | Perceived Quality of Life (PQOL) | ↔ | ↔ 6 months post-treatment
Functional-experiential vs. Cognitive-didactic71 | RCT 360 American Veterans Affairs inpatients (active duty or veteran) with non-penetrating TBI within the preceding 6 months. | Disability Rating Scale (DRS) | NR | ↔ 1 year post-treatment
Functional-experiential vs. Cognitive-didactic71 | | Quality of Life | NR | ↔ 1 year post-treatment
Telephone counseling vs. Standard rehabilitation alone81 RCT | 171 moderate to severe TBI patients discharged from acute care unit. | EuroQoL | NR | ↑ 1 year post injury
Telephone counseling vs. Standard rehabilitation alone81 RCT | | GOS-E | NR | ↑ 1 year post injury
Telephone counseling vs. Standard rehabilitation alone81 RCT | | PQOL | NR | ↑ 1 year post injury
Outreach vs. Information82 | 112 TBI patients with long-term treatment goals amenable to intervention. | BICRO-39 change score | NR | ↑ 2 years post allocation
Case management Versus Conventional rehabilitation 73 RCT (hospitals, not patients) | 126 British TBI patients with closed head injury. Case-managed patients were more severely injured at study entry (Glasgow coma score and amnesia P<0.05 between groups). | GOS-E | ↔ 6 months post injury | ↔ 1 year post injury ↔ 2 years post injury
Case management Versus Conventional rehabilitation 73 RCT (hospitals, not patients) | | DRS | NR | ↓ 2 years post injury
Intensive cognitive rehabilitation vs. Standard neurorehabilitation61 | 57 chronically impaired TBI survivors | QCI | ↑ post-treatment

Among studies that also provided primary outcomes, analyses of secondary patient-centered outcomes demonstrated patterns consistent with their primary outcomes. Vanderploeg et al. found no group differences in the DRS or on a measure of life satisfaction at 1 year post-treatment.71 Cicerone et al. found no group differences in PQOL scores, despite noticing greater mean improvements in the ICRP group.70 Greenwood identified no group differences on secondary outcomes, with the exception of a higher DRS score among the control group at 24 months post-treatment;73 however, this measurement is likely biased due an attrition rate of nearly 50 percent. Cicerone et al. found that the standard rehabilitation group had significantly greater QCI scores than the ICRP group.61

Other studies that reported secondary outcomes showed some positive treatment effects. Bell et al. analyzed measures of productivity and community integration in their RCT of a telephone counseling and education program added to a conventional rehabilitation program compared to the conventional program alone.81 Neither of these measures was considered a primary outcome for our review because authors used composite scores for productivity and community integration, inconsistent with our primary outcome criteria. No differences were found between the telephone intervention group and standard rehabilitation group in these composite measures of productivity and community integration. However, the authors identify an overall composite score as the primary outcome in the study, which demonstrated significant improvements among the telephone group. Additionally, this study provided individual scale scores for three secondary outcomes. The telephone group achieved higher adjusted mean scores in quality of life, as measured by the EuroQOL and the PQOL. No group differences were detected on the GOS-E. Powell et al. found median change scores on the BICRO-39 were significantly higher in an outreach group as compared to an information only group at 2 years post-treatment.82

#### Intervention Characteristics

Due to the heterogeneity of the studied interventions, our main findings from the primary studies pertain only to specific intervention characteristics. In general, interventions targeting the earlier postacute phase of recovery showed no significant group differences. Vanderploeg et al. compared two interventions of similar intensity.71 Salazar et al. compared an intensive program to a substantially less intensive home program and found no group differences.72 However, these results might reflect the limited degree of impairment experienced by participants.

The most frequent studied intervention targeted to TBI survivors with chronic impairments from their injuries is the comprehensive holistic day program. One cohort study found a higher proportion productive, but the difference was not significant.77 One RCT demonstrated higher levels of productivity immediately post-treatment. However, comprehensive holistic day-treatment programs did not substantially or permanently improve outcomes when compared to standard multidisciplinary programs.70

Due to limited evidence, lack of clear findings about comparative effectiveness, and heterogeneity in populations, interventions, comparisons, and outcomes definitions, we could not assess the impact of program intensity or duration on effectiveness.

#### Injury Characteristics

Many of the conclusions previously identified for effectiveness and comparative effectiveness re-emerge when specific injury characteristics are considered. For example, many interventions enrolled only those with closed head injuries, and other interventions enrolled only those with severe TBI. Unfortunately, such studies do not allow for meaningful conclusions about which interventions may be most effective for specific injury types, recovery periods, or impairment types and levels, due to the heterogeneity of interventions and the limited findings of effectiveness.

The studies often provided scant or no details about injury characteristics for the enrolled populations, other than severity levels. Often, studies failed to provide cause of injury, area of brain injured, or details regarding sustained impairment.

A few studies reported on post hoc analyses of certain subgroups of patients when evaluating comparative effectiveness. Salazar et al. noticed significant improvements in the return-to-duty rate among more severely injured TBI survivors (those with loss of consciousness greater than 1 hour) enrolled in the in-hospital program versus the home program (80 percent versus 58 percent, p=.05).72 Cicerone et al. placed more chronically impaired individuals in the ICRP program, some of whom had failed to resume functioning after completing previous postacute treatments.61 These more impaired TBI survivors had higher mean change scores in the CIQ than those enrolled in the standard rehabilitation program. This may be an indication that individuals with more severe impairments are more likely to benefit from a program like the ICRP. The study conducted by Powell et al., restricted to those with severe TBI, found an improved BICRO-39 score among those enrolled in the outreach program versus the information-only program.82 Not all analyses of more severely injured TBI survivors suggest group differences. Rattock et al. detected no differences in productivity across different treatment mixes delivered to severe TBI survivors.79 However, lack of statistically significant differences in employment rates may have resulted from inadequate power.

#### Patient Characteristics

Studies were less likely to be restricted or analyzed based on specific patient characteristics. The two largest RCTs enrolled either only active-duty military personnel or a combination of active-duty military personnel and veterans.71, 72 These two studies provided key findings to our main analysis that are most relevant to military and veteran populations.

Vanderploeg, et al. identified another important patient characteristic during post hoc exploratory analyses. Younger patients enrolled in the cognitive-didactic arm had significantly greater rates of return to work or school than those in the functional-experiential arm.

## Key Question 3 What evidence exists to establish a minimum clinically important difference in community reintegration as measured by the Mayo-Portland Adaptability Inventory (MPAI-4) for postacute rehabilitation for TBI in adults?

### Key Points

- We found no eligible studies that measured effectiveness using the MPAI.
- MCID does not appear to be established for the MPAI.
- MCID in CIQ scores is addressed in one eligible study.

### Detailed Analysis

None of the eligible studies addressed MCID for the MPAI. Because we did not find studies assessing community integration with the MPAI, we evaluated MCID with respect to the CIQ. In their pilot study of the ICRP in which they evaluated the incidence of clinically significant changes in community integration, Cicerone and colleagues derived a “reliable change index” of 4.2 in total CIQ score (from psychometric data from a previous sample of TBI patients). The authors described the reliable change index that indicated whether individuals made positive change, no change, or negative change in community integration in a previous sample of TBI survivors. The authors cited the consistency of this MCID with another that was derived from a previous study.61 However, the later RCT evaluating the ICRP did not mention a reliable change index or other attempts to assess MCID, nor did it explain the omission.70

## Key Question 4 Are improvements in outcomes achieved via multidisciplinary postacute rehabilitation for TBI sustained over time?

### Key Points

- Only two eligible studies with moderate or low risk of bias reported participation outcomes measured at post-treatment and followup intervals.
- A low level of evidence showed that statistically significant improvements immediately post-treatment in CIQ scores and community-based employment were sustained. However, these variables no longer differed between groups at 6 months.
- We found a low strength of evidence that rates of participation in competitive work achieved at 6 months post-treatment were sustained at 12 months post-treatment.73

### Detailed Analysis

Two primary outcomes studies incorporated additional followup outcomes measurements for productivity.70, 73 Table 14 presents the sustainability results for these studies. Cicerone et al. assessed community-based employment immediately post-treatment and again at 6 months post-treatment.70 Improvements in both the ICRP and the standard rehabilitation groups were maintained at 6 months. Greenwood and colleagues assessed outcomes at 6, 12, and 24 months postinjury;73 however, the 24-month measures were considered high risk of bias due to limited data. Both groups appeared to have maintained productivity outcomes from the 6-month postinjury measurement. Cicerone et al. also report a followup assessment of community integration.70 Table 15 describes the sustainability results of this study. Table 16 presents individual components and an overall SOE for each of these comparisons. The study conducted by Cicerone, et al., provides a low SOE that outcomes achieved at completion of the ICRP or standard rehabilitation were sustained at 6 months. Evidence was insufficient to conclude whether outcomes for case management or standard rehabilitation alone were maintained at followup.

Table 14 Sustainability of productivity outcomes

Study Outcome | Treatment Arms | Productive at Timepoint 1 | Productive at Timepoint 2 | Posttreament Vs. Followup
Cicerone 2008^70^ Community-based employment^a^ | Intensive cognitive rehabilitation | 47% (16/34) | 60% (18/30) | P=0.57
Cicerone 2008^70^ Community-based employment^a^ | Standard neurorehabilitation | 21% (7/34) | 50% (14/28) | P=0.10
Greenwood 1994^73^ At competitive work | Case management | 24% (10/42) | 30% (9/30) | P=0.65
Greenwood 1994^73^ At competitive work | Conventional rehabilitation | 28% (15/53) | 30% (14/47) | P=0.90

a Timepoint 1 – immediately post-treatment; Timepoint 2 – 6 months post-treatment.

b Timepoint 1 – 6 months postinjury; Timepoint 2 – 12 months postinjury.

RR = relative risk [95% confidence intervals].

Note: This table reports the outcomes from studies with followup measurements of productivity outcomes.

Table 15 Sustainability of community integration questionnaire score

Study Outcome Measurement | Treatment Arms | Score (SD), Timepoint 1^a^ | Score (SD), Timepoint 2^a^ | Sustainability of Treatment at Timepoint 1
Cicerone 2008^70^ | Intensive Cognitive Rehabilitation Program (n = 34) | 12.9 (3.4) | 13.2 (4.3) | At the 6-month followup, scores remained significantly different from pretreatment (P = .02)
Cicerone 2008^70^ | Standard Neurorehabilitation Program (n = 34) | 11.7 (4.4) | 12.9 (4.4) | At the 6 month followup, participants showed improvement on CIQ scores from post-treatment (P = 0.04)

a Timepoint 1 – immediately post-treatment; Timepoint 2 – 6 months post-treatment.

Note: This table reports the outcomes from studies that with followup measurements of community integration outcomes.

Table 16 Strength of evidence for sustainability outcomes

Intervention Outcome Assessment | Treatment Arms | Study Type | n | Summary Statistics | Risk of Bias | Directness | Precision | Consistency | Evidence Rating
Cicerone 2008^70^ Community-based employment 6 months post-treatment | Intensive cognitive rehabilitation vs. Standard neurorehabilitation | RCT | 58 | RR: 1.22 [0.75 to 1.92] | moderate^*^ | direct | imprecise | NA | Low
Cicerone 2008^70^ CIQ 6 months post-treatment | Intensive cognitive rehabilitation vs. Standard neurorehabilitation | RCT | 58 | ES: 0.07 [−0.41 to 0.54] | moderate^*^ | direct | imprecise | NA | Low
Greenwood, 1994^73^ Post-injury, 1 year | Case-management vs. Conventional rehabilitation | RCT (Hospitals, not patients) | 77 | RR: 1.01 [0.50 to 2.03] | moderate | direct | imprecise | NA | Low

RR = risk ratio [95 percent confidence intervals]

* Moderate risk of bias indicates that the results are probably believable taking study limitations into consideration (low risk of bias would indicate that the results are believable taking study limitations into consideration and high risk of bias would indicate that the results are uncertain taking study limitations into consideration)

## Key Question 5 What adverse effects are associated with multidisciplinary postacute rehabilitation for TBI?

### Key Points

Adverse events of postacute rehabilitation treatments are inadequately addressed in research. We identified one study that formally addressed adverse events.

### Detailed Analysis

The single study that described adverse events did not appear to assess them in a systematic manner, and reported that no adverse events were observed.71