# References

1 Menon DK, Schwab K, Wright DW, et al. Position statement: definition of traumatic brain injury. Archives of Physical Medicine & Rehabilitation. Nov. 2010;91(11):1637-40. [pmid: 21044706].
2 Faul M, Xu L, Wald M, et al. Traumatic Brain Injury in the United States: Emergency Department Visits, Hospitalizations and Deaths 2002–2006 Centers for Disease Control and Prevention, National Center for Injury Prevention and Control. Atlanta, GA. Centers for Disease Control and Prevention NCfIPaC. 2010.
3 Defense and Veterans Brain Injury Center. DoD Worldwide Numbers for TBI (non-combat and combat injuries). Defense and Veterans Brain Injury Center. 2012. http://www.dvbic.org/TBI-Numbers.aspx. Accessed on March 26 2012.
4 Orman JAL, Kraus JF, Zaloshnja E, et al. Epidemiology. Silver JM, McAllister TW, Yudofsky SC, editors. Textbook of traumatic brain injury. 2nd ed. Washington, DC. American Psychiatric Pub. 2011:3-22.
5 Sayer NA, Chiros CE, Sigford B, et al. Characteristics and rehabilitation outcomes among patients with blast and other injuries sustained during the Global War on Terror. Archives of Physical Medicine & Rehabilitation. Jan. 2008;89(1):163-70. [pmid: 18164349].
6 Corrigan JD, Selassie AW, Orman JAL. The epidemiology of traumatic brain injury. Journal of Head Trauma Rehabilitation. Mar–Apr. 2010;25(2):72-80. [pmid: 20234226].
7 Sherer M, Struchen MA, Yablon SA, et al. Comparison of indices of traumatic brain injury severity: Glasgow Coma Scale, length of coma and post-traumatic amnesia. Journal of Neurology, Neurosurgery & Psychiatry. Jun. 2008;79(6):678-85. [pmid: 17928328].
8 Masel BE, DeWitt DS. Traumatic brain injury: a disease process, not an event. Journal of Neurotrauma. Aug. 2010;27(8):1529-40. [pmid: 20504161].
9 Kraus J, Chu L. Chapter 1: Epidemiology. Silver JM, McAllister TW, CYS, editors. Textbook of traumatic brain injury. 1st ed. Washington, DC. American Psychiatric Pub. 2005:3-26.
10 Whyte J, Hart T, Laborde A, et al. Chapter 78: Rehabilitation Issues in Traumatic Brain Injury. DeLisa J, Gans B, Walsh N, Bockenek W, Frontera W, Geriringer S, et al., editors. Physical Medicine & Rehabilitation: Principles and Practice. 4 ed. Philadelphia. Lippincott Williams & Wilkins. 2005:1678-713.
11 Institute of Medicine. Epidemiology of Adult Traumatic Brain Injury Gulf War and health, Volume 7: Long-term consequences of traumatic brain injury. Washington, DC. National Academy Press. 2009:1. online resource (xiii, 381 p.).
12 Chesnut RM CN, Maynard H, et al. Rehabilitation for traumatic brain injury. 2. Research AfHCPa. 1999.
13 High WM Jr. History of Rehabilitation for Traumatic Brain Injury, Rehabilitation for traumatic brain injury. New York, NY. Oxford University Press US. 2005:3-13.
14 Turner-Stokes L, Nair A, Sedki I, et al. Multi-disciplinary rehabilitation for acquired brain injury in adults of working age (Review). 2011.
15 Malec JF, Basford JS. Postacute brain injury rehabilitation. Archives of Physical Medicine & Rehabilitation. Feb. 1996;77(2):198-207. [pmid: 8607747].
16 Washington AE, Lipstein SH. The Patient-Centered Outcomes Research Institute--promoting better information, decisions, and health. New England Journal of Medicine. Oct. 13. 2011;365(15):e31. [pmid: 21992473].
17 World Health Organization. International classification of functioning, disability and health: ICF. World Health Organization. 2001.
18 Novack TA, Bush BA, Meythaler JM, et al. Outcome after traumatic brain injury: pathway analysis of contributions from premorbid, injury severity, and recovery variables. Archives of Physical Medicine & Rehabilitation. Mar. 2001;82(3):300-5. [pmid: 11245749].
19 Sander AM, Clark A, Pappadis MR. What is community integration anyway?: defining meaning following traumatic brain injury. Journal of Head Trauma Rehabilitation. Mar–Apr. 2010;25(2):121-7. [pmid: 20134333].
20 Cicerone KD. Participation as an outcome of traumatic brain injury rehabilitation. Journal of Head Trauma Rehabilitation. Nov–Dec. 2004;19(6):494-501. [pmid: 15602311].
21 Heinemann AW. Measurement of participation in rehabilitation research. Archives of Physical Medicine & Rehabilitation. Sep. 2010;91(9 Suppl):S1-4. [pmid: 20801274].
22 Malec J. The Mayo Portland Adaptability Inventory. The Center for Outcome Measurement in Brain Injury. 2005. http://www.tbims.org/combi/mpai. Accessed June 5, 2012.
23 Rehabilitation Institute of Chicago Center for Rehabilitation Outcomes Research. Rehab Measures: Community Integration Questionnaire. Chicago. Northwestern University Feinberg School of Medicine Department of Medical Social Sciences Informatics group. 2010. http://www.rehabmeasures.org/Lists/RehabMeasures/PrintView.aspx?ID=894. Accessed on October 20, 2011.
24 Revicki D, Hays RD, Cella D, et al. Recommended methods for determining responsiveness and minimally important differences for patient-reported outcomes. Journal of Clinical Epidemiology. Feb. 2008;61(2):102-9. [pmid: 18177782].
25 Beaton DE, Boers M, Wells GA. Many faces of the minimal clinically important difference (MCID): a literature review and directions for future research. Current Opinion in Rheumatology. Mar. 2002;14(2):109-14. [pmid: 11845014].
26 Cifu DX, Cohen SI, Lew HL, et al. The History and Evolution of Traumatic Brain Injury Rehabilitation in Military Service Members and Veterans. American Journal of Physical Medicine & Rehabilitation. Aug. 2010;89(8):688-94. [pmid: 20647782].
27 Vaughn SL, Reynolds WE, Cope DN. Systems of Care. Silver JM, McAllister TW, CYS, editors. Textbook of Traumatic Brain Injury. Washington, DC. American Psychiatric Publishing, Inc. 2010:505-20.
28 Miller TC, Zwerdling D. Pentagon Health Plan Won’t Cover Brain-Damage Therapy for Troops. Washington DC. National Public Radio. 2010. http://www.npr.org/2010/12/20/132145959/pentagon-health-plan-wont-cover-brain-damage-therapy-for-troops. Accessed on October 27 2011.
29 Turner-Stokes L, Disler PB, Nair A, et al. Multi-disciplinary rehabilitation for acquired brain injury in adults of working age. Cochrane Database of Systematic Reviews. 2005;(3):CD004170. [pmid: 16034923].
30 Turner-Stokes L. Evidence for the effectiveness of multi-disciplinary rehabilitation following acquired brain injury: a synthesis of two systematic approaches. Journal of Rehabilitation Medicine. Oct. 2008;40(9):691-701. [pmid: 18843419].
31 Geurtsen GJ, van Heugten CM, Martina JD, et al. Comprehensive rehabilitation programmes in the chronic phase after severe brain injury: a systematic review. Journal of Rehabilitation Medicine. Feb. 2010;42(2):97-110. [pmid: 20140404].
32 Doig E, Fleming J, Kuipers P, et al. Comparison of rehabilitation outcomes in day hospital and home settings for people with acquired brain injury - a systematic review. Disability & Rehabilitation. 2010;32(25):2061-77. [pmid: 20441412].
33 Evans L, Brewis C. The efficacy of community-based rehabilitation programmes for adults with TBI. 2008.
34 Cicerone KD, Azulay J, Trott C. Methodological quality of research on cognitive rehabilitation after traumatic brain injury. Archives of Physical Medicine & Rehabilitation. Nov. 2009;90(11 Suppl):S52-9. [pmid: 19892075].
35 Cicerone KD, Dahlberg C, Kalmar K, et al. Evidence-based cognitive rehabilitation: recommendations for clinical practice. Archives of Physical Medicine & Rehabilitation. Dec. 2000;81(12):1596-615. [pmid: 11128897].
36 Cicerone KD, Dahlberg C, Malec JF, et al. Evidence-based cognitive rehabilitation: updated review of the literature from 1998 through 2002. Archives of Physical Medicine & Rehabilitation. Aug. 2005;86(8):1681-92. [pmid: 16084827].
37 Cicerone KD, Langenbahn DM, Braden C, et al. Evidence-based cognitive rehabilitation: updated review of the literature from 2003 through 2008. Archives of Physical Medicine & Rehabilitation. Apr. 2011;92(4):519-30. [pmid: 21440699].
38 Institute of Medicine. Cognitive Rehabilitation Therapy for Traumatic Brain Injury: Evaluating the Evidence. Washington, DC. National Academies Press. 2011.
39 ECRI Institute. Cognitive Rehabilitation for the Treatment of Traumatic Brain Injury. ECRI Institute. October. 2. 2009. 2009.
40 Cattelani R, Zettin M, Zoccolotti P. Rehabilitation treatments for adults with behavioral and psychosocial disorders following acquired brain injury: a systematic review. Neuropsychology Review. Mar. 2010;20(1):52-85. [pmid: 20143264].
41 Fadyl JK, McPherson KM. Approaches to vocational rehabilitation after traumatic brain injury: a review of the evidence. Journal of Head Trauma Rehabilitation. May–Jun. 2009;24(3):195-212. [pmid: 19461367].
42 Kim H, Colantonio A. Effectiveness of rehabilitation in enhancing community integration after acute traumatic brain injury: a systematic review. American Journal of Occupational Therapy. Sep–Oct. 2010;64(5):709-19. [pmid: 21073101].
43 Lippert C, Weiser M, McCabe P, et al. Community Integration Following ABI. London, Ontario, Canada. 2011. http://www.abiebr.com/.
44 ABIER. Evidence-Based Reveiw of Moderate to Severe Acquired Brain Injury. 2011. http://www.abiebr.com/. Accessed on October 28, 2011.
45 Cullen NK, Park YG, Bayley MT. Functional recovery following traumatic vs non-traumatic brain injury: a case-controlled study. Brain Injury. 2008;22(13–14):1013-20. [pmid: 19117180].
46 O’Connor D, Green S, Higgins JP. Chapter 5: Defining the review question and developing criteria for including studies. Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions: Version 5.1.0. The Cochrane Collaboration. 2011.
47 Bender R, Bunce C, Clarke M, et al. Attention should be given to multiplicity issues in systematic reviews. Journal of Clinical Epidemiology. Sep. 2008;61(9):857-65. [pmid: 18687287].
48 Evans RW. Postacute neurorehabilitation: roles and responsibilities within a national information system. Archives of Physical Medicine & Rehabilitation. Aug. 1997;78(8 Suppl 4):S17-25. [pmid: 9270484].
49 Wilde E, Whiteneck G, Bogner J, et al. Recommendations for the Use of Common Outcome Measures in Traumatic Brain Injury Research. Archives of Physical Medicine and Rehabilitation. 2010;91(11):1650-60. [pmid: 21044708].
50 Rehabilitation Measures Database Rehab Measures: Craig Handicap Assessment and Reporting Technique. Chicago. Rehabilitation Institute of Chicago. 2010. http://www.rehabmeasures.org/Lists/RehabMeasures/DispForm.aspx?ID=963&Source=http%3A%2F%2Fwww%2Erehabmeasures%2Eorg%2Frehabweb%2Fallmeasures%2Easpx%3FPageView%3DShared. Accessed on October 27, 2011.
51 Dijkers M. The Community Integration Questionnaire. 2000. http://www.tbims.org/combi/ciq. Accessed on October 27, 2011.
52 Mellick D. The Craig Handicap Assessment and Reporting Technique - Short Form. The Center for Outcome Measurement in Brain Injury. 2000. http://tbims.org/combi/chartsf/.
53 Rehabilitation Institute of Chicago Center for Rehabilitation Outcomes Research. Rehab Measures: Craig Handicap Assessment and Reporting Technique. Chicago. Northwestern University Feinberg School of Medicine Department of Medical Social Sciences Informatics group. 2010. http://www.rehabmeasures.org/Lists/RehabMeasures/DispForm.aspx?ID=963&Source=http%3A%2F%2Fwww%2Erehabmeasures%2Eorg%2Frehabweb%2Fallmeasures%2Easpx%3FPageView%3DShared. Accessed on October 20, 2011.
54 Wright J, Bushnik T, O’Hare P. The Center for Outcome Measurement in Brain Injury (COMBI): An Internet resource you should know about. Journal of Head Trauma Rehabilitation. Feb. 2000;15(1):734-8. [pmid: 10745188].
55 Mellick D. The Craig Handicap Assessment and Reporting Technique. The Center for Outcome Measurement in Brain Injury. 2000. http://tbims.org/combi/chart/index.html.
56 Malec J. The Mayo Portland Adaptability Inventory. The Center for Outcome Measurement in Brain Injury. 2005. http://www.tbims.org/combi/mpai. Accessed on October 20, 2011.
57 Powell JH, Beckers K, Greenwood RJ. Measuring progress and outcome in community rehabilitation after brain injury with a new assessment instrument--the BICRO-39 scales. Brain Injury Community Rehabilitation Outcome. Archives of Physical Medicine & Rehabilitation. Oct. 1998;79(10):1213-25. [pmid: 9779674].
58 Wright J. The Disability Rating Scale. The Center for Outcome Measurement in Brain Injury. 2000. http://tbims.org/combi/drs/.
59 Sander A. Extended Glasgow Outcome Scale. The Center for Outcome Measurement in Brain Injury. 2002. http://tbims.org/combi/gose/index.html.
60 Semlyen JK, Summers SJ, Barnes MP. Traumatic brain injury: efficacy of multidisciplinary rehabilitation. Archives of Physical Medicine & Rehabilitation. Jun. 1998;79(6):678-83. [pmid: 9630149].
61 Cicerone KD, Mott T, Azulay J, et al. Community integration and satisfaction with functioning after intensive cognitive rehabilitation for traumatic brain injury. Archives of Physical Medicine & Rehabilitation. Jun. 2004;85(6):943-50. [pmid: 15179648].
62 University of Pennsylvania Positive Psychology Center. Positive Psychology Questionnaires. 2007. http://www.ppc.sas.upenn.edu/ppquestionnaires.htm#QOLI. Accessed on December 7, 2011.
63 Viswanathan M, Ansari M, Berkman N, et al. Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions AHRQ. 2012.
64 Higgins JPT, Altman D, Sterne J. Chapter 8: Assessing risk of bias in included studies. Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions: Version 5.1.0. The Cochrane Collaboration. 2011.
65 Viswanathan M, Berkman ND. Development of the RTI item bank on risk of bias and precision of observational studies. Journal of Clinical Epidemiology. 2011.
66 Hart T. Treatment definition in complex rehabilitation interventions. Neuropsychological Rehabilitation. Dec. 2009;19(6):824-40. [pmid: 19544183].
67 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective health-care program. Journal of Clinical Epidemiology. May. 2010;63(5):513-23. [pmid: 19595577].
68 Schünemann H, Brożek J, Oxman A. GRADE handbook for grading quality of evidence and strength of recommendation. Version 3.2. The GRADE Working Group. 2009.
69 Atkins D, Chang S, Gartlehner G, et al. Assessing the Applicability of Studies When Comparing Medical Interventions. Quality AfHRa. December. 2010. http://www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayProduct&productID=603#2412.
70 Cicerone KD, Mott T, Azulay J, et al. A randomized controlled trial of holistic neuropsychologic rehabilitation after traumatic brain injury. Archives of Physical Medicine & Rehabilitation. Dec. 2008;89(12):2239-49. [pmid: 19061735].
71 Vanderploeg RD, Schwab K, Walker WC, et al. Rehabilitation of traumatic brain injury in active duty military personnel and veterans: Defense and Veterans Brain Injury Center randomized controlled trial of two rehabilitation approaches. Archives of Physical Medicine & Rehabilitation. Dec. 2008;89(12):2227-38. [pmid: 19061734].
72 Salazar AM, Warden DL, Schwab K, et al. Cognitive rehabilitation for traumatic brain injury: A randomized trial. Defense and Veterans Head Injury Program (DVHIP) Study Group. JAMA. Jun. 21. 2000;283(23):3075-81. [pmid: 10865301].
73 Greenwood RJ, McMillan TM, Brooks DN, et al. Effects of case management after severe head injury. BMJ. May. 7. 1994;308(6938):1199-205. [pmid: 8180536].
74 Ponsford J, Harrington H, Olver J, et al. Evaluation of a community-based model of rehabilitation following traumatic brain injury. Neuropsychological Rehabilitation. Jun. 2006;16(3):315-28. [pmid: 16835154].
75 Hashimoto K, Okamoto T, Watanabe S, et al. Effectiveness of a comprehensive day treatment program for rehabilitation of patients with acquired brain injury in Japan. Journal of Rehabilitation Medicine. Jan. 2006;38(1):20-5. [pmid: 16548082].
76 Sarajuuri JM, Kaipio M-L, Koskinen SK, et al. Outcome of a comprehensive neurorehabilitation program for patients with traumatic brain injury. Archives of Physical Medicine & Rehabilitation. Dec. 2005;86(12):2296-302. [pmid: 16344026].
77 Prigatano GP, Fordyce DJ, Zeiner HK, et al. Neuropsychological rehabilitation after closed head injury in young adults. Journal of Neurology, Neurosurgery & Psychiatry. May. 1984;47(5):505-13. [pmid: 6736983].
78 Prigatano GP, Klonoff PS, O’Brien KP, et al. Productivity after neuropsychologically oriented milieu rehabilitation. The Journal of Head Trauma Rehabilitation. Mar. 1994;9(1):91-102.
79 Rattok J, Ross B, Ben-Yishay Y, et al. Outcome of different treatment mixes in a multidimensional neuropsychological rehabilitation program. Neuropsychology. 1992;6(4):395.
80 Willer B, Button J, Rempel R. Residential and home-based postacute rehabilitation of individuals with traumatic brain injury: a case control study. Archives of Physical Medicine & Rehabilitation. Apr. 1999;80(4):399-406. [pmid: 10206601].
81 Bell KR, Temkin NR, Esselman PC, et al. The effect of a scheduled telephone intervention on outcome after moderate to severe traumatic brain injury: a randomized trial. Archives of Physical Medicine & Rehabilitation. May. 2005;86(5):851-6. [pmid: 15895327].
82 Powell J, Heslin J, Greenwood R. Community based rehabilitation after severe traumatic brain injury: a randomised controlled trial. Journal of Neurology, Neurosurgery & Psychiatry. Feb. 2002;72(2):193-202. [pmid: 11796769].
83 Thomas M. The Potential Unlimited Programme: an outdoor experiential education and group work approach that facilitates adjustment to brain injury. Brain Injury. Dec. 2004;18(12):1271-86. [pmid: 15666570].
84 Agency for Healthcare Research and Quality. Assessing Equivalence and Non-Inferiority draft report AHRQ. 2011. www.effectivehealthcare.ahrq.gov/ehc/.
85 Rohling ML, Faust ME, Beverly B, et al. Effectiveness of cognitive rehabilitation following acquired brain injury: a meta-analytic re-examination of Cicerone et al.’s (2000, 2005) systematic reviews. Neuropsychology. Jan. 2009;23(1):20-39. [pmid: 19210030].
86 Corrigan JD, Deutschle JJ Jr. The presence and impact of traumatic brain injury among clients in treatment for co-occurring mental illness and substance abuse. Brain Injury. Mar. 2008;22(3):223-31. [pmid: 18297594].
87 Kane RL. Assessing the effectiveness of postacute care rehabilitation. Archives of Physical Medicine & Rehabilitation. Nov. 2007;88(11):1500-4. [pmid: 17964896].
88 Whiteneck G, Dijkers M, Gassaway J, et al. The SCIRehab Project: classification and quantification of spinal cord injury rehabilitation treatments. Preface Journal of Spinal Cord Medicine. 2009;32(3):249-50. [pmid: 19810626].
89 Pawson R, Greenhalgh T, Harvey G, et al. Realist review--a new method of systematic review designed for complex policy interventions. Journal of Health Services & Research Policy. Jul. Suppl 1. 2005;10:21-34. [pmid: 16053581].
90 Boutron I, Moher D, Altman DG, et al. Extending the CONSORT statement to randomized trials of nonpharmacologic treatment: explanation and elaboration. Annals of Internal Medicine. Feb. 19. 2008;148(4):295-309. [pmid: 18283207].
91 Horn SD, Gassaway J. Practice based evidence: incorporating clinical heterogeneity and patient-reported outcomes for comparative effectiveness research. Medical Care. Jun. 2010;48(6 Suppl):S17-22. [pmid: 20421825].
92 Hammond FM, Malec JF. The Traumatic Brain Injury Model Systems: a longitudinal database, research, collaboration and knowledge translation. European journal of physical & rehabilitation medicine. Dec. 2010;46(4):545-8. [pmid: 21224786].