# Future Research

Many systematic reviews have synthesized existing evidence for effectiveness and comparative effectiveness of multidisciplinary postacute rehabilitation for moderate to severe TBI in adults. Past reviews have had different focal points and eligibility criteria. The recently conducted IOM review of cognitive rehabilitation for TBI impairments was not able to draw conclusions about the effectiveness or comparative effectiveness of comprehensive multimodal programs for those with moderate to severe injuries, (the section of that review overlapping this review). Despite many reviews, research gaps remain. Additional comparative effectiveness reviews cannot satisfy these gaps until more high quality studies are completed. A followup study and report outlining the future research needs for this topic is forthcoming. Collaborative efforts among payers, providers, and other decisionmakers will enhance the value of future efforts. Conceptual work to overcome the shortcomings of current research may be the highest priority. Formal evidence synthesis efforts should aim to identify combinations of patient groups and rehabilitation approaches most likely to achieve success. Effectiveness trials can then be conducted for these high-priority subgroups and interventions. Future effectiveness and comparative effectiveness studies need to address the shortcomings of the currently available literature.

Conceptual work could assist an advancing knowledge in the field by making comparative effectiveness research more useful. For example, the development and consistent use of standardized assessments of TBI impairments could foster consistent reporting in research. The Interagency Workgroup on Demographics and Clinical Assessment has recently provided recommendations to achieve this standardization. Standardization would enable researchers to better define impairment domains and levels of impairment, which is critical to understanding which interventions work best for which patients. Additionally, as with many postacute rehabilitation topics, the taxonomy of treatment is underdeveloped.87 Future research should work across all relevant disciplines to advance the development and consistent use of a taxonomy for rehabilitation interventions. This taxonomy would enhance patients’ understanding of rehabilitation programs and enable more informed decisionmaking. The recent effort to develop unique taxonomies relevant to spinal cord injury rehabilitation could inform similar efforts specific to TBI rehabilitation.88

Future evidence synthesis efforts could address questions relevant to the current state of the research on this topic. For example, realist reviews are well suited to complex interventions (characterized as programs in which effects are dependent on context and implementation).89 Realist reviews seek to provide an explanatory analysis discerning what works for whom and under what circumstances. This information can help strengthen understanding of programs and inform efficient and effective implementation.89 Although realist reviews cannot achieve the goal of comparative effectiveness reviews, which is to identify what works and what does not, they can generate information that spurs hypotheses from which to design comparative effectiveness studies.

Future effectiveness and comparative effectiveness studies should aim to decrease risk of bias in individual studies and to expand sample sizes. Given the complexity of TBI and the interventions to address persistent impairments, and the heterogeneity common in these patients, the most valuable studies may those that aim to answer the question of which programs work for which impairments and types of patients or injuries. RCTs could be designed to address these questions. However, additional small RCTs alone may not move the field forward toward a substantially stronger evidence base. The construction of a sufficient evidence base will require reconsideration of common methodological practices that have weakened RCT evidence, including 1) the specificity of populations studied, interventions compared, and outcomes used to measure effectiveness, and 2) small sample sizes. Large RCTs may be able to address these issues and thus provide stronger evidence. Larger sample sizes in RCTs that collect and report data elements relevant to patients, injuries, and interventions would allow for statistical adjustment of key confounding variables and may provide sufficient power to explore subgroup differences in treatment response. The expanded CONSORT statement provides guidance on reporting for RCTs evaluating nonpharmacological treatments.90 Resulting data could then be used to statistically control for the many confounding variables inherent to this complex condition and interventions. However, specific alternatives to RCTs have been proposed as better suited to provide higher quality comparative effectiveness evidence with these complex topics. For example, the practice-based evidence approach91 may help overcome certain shortcomings of the available research, also in part by allowing for studies with larger sample sizes.

The addition of high quality prospective cohort studies—if conducted on a broader scale—could also add valuable information about specific interventions and subgroups of TBI survivors. Therefore, several steps should be taken to correct common methodological flaws and to address unanswered questions. First, research on TBI rehabilitation must be appropriately powered to detect differences between treatment groups. Constructing research studies with adequate numbers in relevant subgroups or with sample sizes large enough to adjust for these differences would allow more meaningful results and conclusions. Cohort studies should carefully select comparison groups as similar as possible to the treatment group.

Both future RCTs and prospective cohort studies should address other methodological issues that currently detract from the current body of evidence. The adequacy of treatment definitions varied widely across studies. While some studies provided substantial details about their interventions, we would like to see references to treatment manuals (i.e. manualized interventions) that provide a resource for determining specific treatment components and content, including: (1) the “how and why” of what is implemented for specific patients; (2) treatment progress; and (3) injury or impairment characteristics. Adequately defining the intervention would also assist in promoting the effective implementation of the interventions and control conditions and enable studies to evaluate the importance of intervention characteristics. Adherence or fidelity checks for the treatment and control conditions would verify the effective implementation of the compared interventions. Attention to these intervention definition and implementation issues would reduce risk of bias for intervention studies and enhance replicability of successful programs. While blinding of participants and providers may not be feasible, outcome assessors can and should be blinded. A lower risk of bias related to outcomes in these intervention studies could be achieved through a priori selection of primary patient-centered outcomes; a limited number of outcomes scales and comparisons; use of consistent and appropriate psychometrically justifiable outcomes scales; the establishment of minimum clinically important differences in these scales; and the adjustment for multiple comparisons. All of this would help create a stronger evidence base.

The TBI Model Systems programs.92 may offer a venue for conducting rigorously designed comparative effectiveness studies, but are not without limitations (e.g., limited resources, systems not designed for intervention research). Future research should continue to explore comparative effectiveness by comparing interventions implemented in different TBI model systems locations. Secondary analysis of individual patient data could reveal patterns among patient, injury, and rehabilitation characteristics that are associated with improved outcomes. However, systems that capture the necessary intervention level information may not yet exist. Large RCTs and prospective cohort designs with appropriate controls would best move the field forward.