# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project:

## Key Informants

Allen W. Brown, M.D.

Director of Brain Rehabilitation Services and Research Program

Department of Physical Medicine and Rehabilitation

Mayo Clinic

Rochester, MN

Kathleen Golisz, OTR/L, OTD

Associate Director/Director of Clinical Education/Professor

Occupational Therapy Program, Mercy College

Dobbs Ferry, NY

Alison N. Cernich, Ph.D., ABPP-Cn

Director, Neuropsychology, VA Maryland Health Care System

Assistant Professor, Departments of Neurology and Psychiatry

University of Maryland School of Medicine

Baltimore, MD

Joseph H. Ricker, Ph.D., ABPP (CN, RP)

Associate Director for Research

Vice Chair for Neuropsychology and Rehabilitation Psychology

Department of Physical Medicine and Rehabilitation

University of Pittsburgh School of Medicine

Pittsburgh, PA

Mary Vining Radomski, Ph.D., OTR/L

Clinical Scientist, Sister Kenny Research Center

Minneapolis, MN

Anonymous Patient Caregiver

Portland, OR

## Technical Expert Panel

Beth M. Ansel Ph.D.

Director, Traumatic Brain Injury and Stroke Rehabilitation Program

National Center for Medical Rehabilitation Research

National Institute of Child Health and Human Development

National Institutes of Health

Bethesda, MD

Douglas E. Bidelspach, M.P.T.

Rehabilitation Planning Specialist-Data Manager

Department of Veterans Affairs

Lebanon, PA

David Xavier Cifu, M.D.

Chairman and Herman J. Flax, M.D.

Professor, Department of Physical Medicine and Rehabilitation

Virginia Commonwealth University School of Medicine

Chief of PM&R Services, VCU Health System

Executive Director, VCU-Center for Rehabilitation Sciences and Engineering

National Director, PM&R Program Office for the Veterans Health Administration

Richmond, VA

Joseph T. Giacino, Ph.D.

Director of Rehabilitation, Physical Medicine, and Rehabilitation

Spaulding Rehabilitation Hospital

Associate Professor, Department of Physical Medicine and Rehabilitation

Harvard Medical School

Boston, MA

Michael T. Handrigan, M.D., FACEP

Commander, U.S. Public Health Service

Traumatic Brain Injury Clinical Standards of Care

Defense Centers of Excellence for PH/TBI

Silver Spring, MD

Mary R.T. Kennedy, Ph.D., CCC-SLP, BC-ANCDS

Associate Professor

Speech-Language-Hearing Sciences and the Center for Cognitive Sciences

University of Minnesota

Minneapolis, MN

Tessa Hart, Ph.D.

Professor, Department of Rehabilitation Medicine

Jefferson Medical College

Director, Traumatic Brain Injury Clinical Research Laboratory and Moss Traumatic Brain Injury Model System

Moss Rehabilitation Research Institute

Elkins Park, PA

Flora Fenner McConnell Hammond, M.D.

Chair, Department of Physical Medicine and Rehabilitation

Chief, Medical Affairs

Indiana University School of Medicine

Indianapolis, IN

John Whyte, M.D., Ph.D.

Attending Physiatrist, Drucker Brain Injury Center

Director, Moss Rehabilitation Research Institute

Elkins Park, PA

## Peer Reviewers

Beth M. Ansel, Ph.D., CCC-SLP

Director, Clinical Practice Program

National Center for Medical Rehabilitation Research (NCMRR)

Bethesda, MA

Douglas E. Bidelspach, M.P.T.

Rehabilitation Planning Specialist–Data Manager

Department of Veterans Affairs

Lebanon, PA

David Xavier Cifu, M.D.

Chairman and Herman J. Flax, M.D. Professor

Department of Physical Medicine and Rehabilitation

Virginia Commonwealth University School of Medicine

Chief of PM&R Services, VCU Health System

Executive Director, VCU-Center for Rehabilitation Sciences and Engineering

National Director, PM&R Program Office for the Veterans Health Administration

Richmond, VA

Joseph T. Giacino, Ph.D.

Director of Rehabilitation, Physical Medicine, and Rehabilitation

Spaulding Rehabilitation Hospital

Associate Professor, Department of Physical Medicine and Rehabilitation

Harvard Medical School

Boston, MA

Michael T. Handrigan, M.D., FACEP

Commander, U.S. Public Health Service

Traumatic Brain Injury Clinical Standards of Care

Defense Centers of Excellence for PH/TBI

Silver Spring, MD

Odette A. Harris, M.D., M.P.H.

Director, Brain Injury, Department of Neurosurgery

Stanford Hospital

Stanford, CA

Lawrence J. Horn, M.D.

Detroit Medical Center; Rehabilitation Institute of Michigan

Physical Medicine and Rehabilitation (PM&R)

Detroit, MI

Mary R.T. Kennedy, Ph.D., CCC-SLP, BC-ANCDS

Associate Professor

Speech-Language-Hearing Sciences and the Center for Cognitive Sciences

University of Minnesota

Minneapolis, MN

Michael O’Dell, M.D.

Adjunct Professor of Rehabilitation Medicine

Columbia University College of Physicians and Surgeons

New York, NY

Joel Scholten, M.D.

Associate Chief of Staff, Rehabilitation Services

Washington DC VA Medical Center

Washington, DC

Karen Lohmann Siegel, P.T., M.A.

CAPT, United States Public Health Service

U.S. Food and Drug Administration/CDRH/OSEL

Silver Spring, MD

Tina M. Trudel, Ph.D.

President/COO, Lakeview Healthcare Systems

Site Director/Principal Investigator, DVBIC at Virginia NeuroCare

Asst. Professor of Psych/Neurobehavioral Sciences

University of Virginia School of Medicine

Richmond, VA

John Whyte, M.D., Ph.D.

Attending Physiatrist

Drucker Brain Injury Center

Director, Moss Rehabilitation Research Institute

Elkins Park, PA

Ross D. Zafonte, D.O.

Vice President of Medical Affairs

Harvard Medical School

Spaulding Rehabilitation Network

Boston, MA