# References to Appendixes

1 Cicerone KD, Mott T, Azulay J, et al. A randomized controlled trial of holistic neuropsychologic rehabilitation after traumatic brain injury. Archives of Physical Medicine & Rehabilitation. Dec. 2008;89(12):2239-49. [pmid: 19061735].
2 Vanderploeg RD, Schwab K, Walker WC, et al. Rehabilitation of traumatic brain injury in active duty military personnel and veterans: Defense and Veterans Brain Injury Center randomized controlled trial of two rehabilitation approaches. Archives of Physical Medicine & Rehabilitation. Dec. 2008;89(12):2227-38. [pmid: 19061734].
3 Salazar AM, Warden DL, Schwab K, et al. Cognitive rehabilitation for traumatic brain injury: A randomized trial. Defense and Veterans Head Injury Program (DVHIP) Study Group. JAMA. Jun. 21. 2000;283(23):3075-81. [pmid: 10865301].
4 Greenwood RJ, McMillan TM, Brooks DN, et al. Effects of case management after severe head injury. BMJ. May. 7. 1994;308(6938):1199-205. [pmid: 8180536].
5 Ponsford J, Harrington H, Olver J, et al. Evaluation of a community-based model of rehabilitation following traumatic brain injury. Neuropsychological Rehabilitation. Jun. 2006;16(3):315-28. [pmid: 16835154].
6 Sarajuuri JM, Kaipio M-L, Koskinen SK, et al. Outcome of a comprehensive neurorehabilitation program for patients with traumatic brain injury. Archives of Physical Medicine & Rehabilitation. Dec. 2005;86(12):2296-302. [pmid: 16344026].
7 Prigatano GP, Klonoff PS, O’Brien KP, et al. Productivity after neuropsychologically oriented milieu rehabilitation. The Journal of Head Trauma Rehabilitation. Mar. 1994;9(1):91-102.
8 Rattok J, Ross B, Ben-Yishay Y, et al. Outcome of different treatment mixes in a multidimensional neuropsychological rehabilitation program. Neuropsychology. 1992;6(4):395.
9 Prigatano GP, Fordyce DJ, Zeiner HK, et al. Neuropsychological rehabilitation after closed head injury in young adults. Journal of Neurology, Neurosurgery & Psychiatry. May. 1984;47(5):505-13. [pmid: 6736983].
10 Hashimoto K, Okamoto T, Watanabe S, et al. Effectiveness of a comprehensive day treatment program for rehabilitation of patients with acquired brain injury in Japan. Journal of Rehabilitation Medicine. Jan. 2006;38(1):20-5. [pmid: 16548082].
11 Cicerone KD, Mott T, Azulay J, et al. Community integration and satisfaction with functioning after intensive cognitive rehabilitation for traumatic brain injury. Archives of Physical Medicine & Rehabilitation. Jun. 2004;85(6):943-50. [pmid: 15179648].
12 Willer B, Button J, Rempel R. Residential and home-based postacute rehabilitation of individuals with traumatic brain injury: a case control study. Archives of Physical Medicine & Rehabilitation. Apr. 1999;80(4):399-406. [pmid: 10206601].
13 Bell KR, Temkin NR, Esselman PC, et al. The effect of a scheduled telephone intervention on outcome after moderate to severe traumatic brain injury: a randomized trial. Archives of Physical Medicine & Rehabilitation. May. 2005;86(5):851-6. [pmid: 15895327].
14 Powell J, Heslin J, Greenwood R. Community based rehabilitation after severe traumatic brain injury: a randomised controlled trial. Journal of Neurology, Neurosurgery & Psychiatry. Feb. 2002;72(2):193-202. [pmid: 11796769].
15 Thomas M. The Potential Unlimited Programme: an outdoor experiential education and group work approach that facilitates adjustment to brain injury. Brain Injury. Dec. 2004;18(12):1271-86. [pmid: 15666570].
16 Semlyen JK, Summers SJ, Barnes MP. Traumatic brain injury: efficacy of multidisciplinary rehabilitation. Archives of Physical Medicine & Rehabilitation. Jun. 1998;79(6):678-83. [pmid: 9630149].