# Evidence Tables

Appendix E. Table 1 Evidence table of multidisciplinary postacute rehabilitation for moderate to severe TBI studies

Appendix E. Table 2 Intervention Characteristics