# Secondary Outcomes

Appendix D. Table 1 Secondary outcomes

Study, Design; [underlined: Instrument] | Treatment Arms | Outcome Before Treatment | Outcome After Completion of Treatment | Treatment vs. Control; Comments
Cicerone 2008,^1^ RCT [underlined: Perceived Quality of Life (PQOL)] post treatment (16 weeks) | Intensive Cognitive Rehabilitation Program (ICRP) (n=34) | 59.0 (21.7) | 66.8 (17.5) P<0.05 versus before treatment | ES=0.26 [−0.22 to 0.74] No significant differences between groups but Intensive cognitive rehabilitation participants showed greater improvements on the PQOL
Cicerone 2008,^1^ RCT [underlined: Perceived Quality of Life (PQOL)] post treatment (16 weeks)
Cicerone 2008,^1^ RCT [underlined: Perceived Quality of Life (PQOL)] post treatment (16 weeks) | Standard Neurorehabilitation Program (STD) (n=34) | 61.2 (16.5) | 62.2 (17.2)
Vanderploeg 2008,^2^ RCT [underlined: Disability Rating Scale (DRS)] 1 year post protocol treatment | Functional-experimental (n=150) | NR | 8.2 (5.3) | ES=0.12 [−0.11 to 0.34] No significant differences between groups (P=0.29)
Vanderploeg 2008,^2^ RCT [underlined: Disability Rating Scale (DRS)] 1 year post protocol treatment
Vanderploeg 2008,^2^ RCT [underlined: Disability Rating Scale (DRS)] 1 year post protocol treatment | Cognitive-didactic (n=152) | NR | 7.6 (4.8)
Vanderploeg 2008,^2^ RCT [underlined: Quality of Life (satisfied with life- yes/no)] 1 year post protocol treatment | Functional-experimental (n=124) | NR | 65% (81/124) | RR = 1.06 [0.88 to 1.28] No significant differences between groups (P=0.53)
Vanderploeg 2008,^2^ RCT [underlined: Quality of Life (satisfied with life- yes/no)] 1 year post protocol treatment
Vanderploeg 2008,^2^ RCT [underlined: Quality of Life (satisfied with life- yes/no)] 1 year post protocol treatment | Cognitive-didactic (n=130) | NR | 62% (80/130)
Powell 2002,^14^ RCT [underlined: Brain injury community rehabilitation outcome-39 (BICRO-39)] 27 weeks post treatment | Outreach (n=35 of 54 randomized) | Median (range) 15.3 (8 to 22.3) | % improving 80.0 (28/35) Median change (range) 2.5 (−1.7 to 6.2) | RR = 1.14 [0.88 to 1.49] Total BICRO-39 change score (summed across the six scales) was significantly greater in the outreach group than in the information group (mean ranks: outreach 43.2, information 33.4; U=517, p=0.05).
Powell 2002,^14^ RCT [underlined: Brain injury community rehabilitation outcome-39 (BICRO-39)] 27 weeks post treatment
Powell 2002,^14^ RCT [underlined: Brain injury community rehabilitation outcome-39 (BICRO-39)] 27 weeks post treatment | Information (n=40 of 56 randomized) | Median (range) 12.9 (8.8 to 25.7) | % improving 70.0 (28/40) Median change (range) 0.9 (−4.1 to 6.8)
Bell 2005^13^ RCT EuroQoL | Telephone | NR | Adjusted mean 0.78 | Treatment effect=0.10 (0.02–0.19)
Bell 2005^13^ RCT EuroQoL
Bell 2005^13^ RCT EuroQoL | Standard | NR | Adjusted mean 0.67
Bell 2005^13^ RCT GOS-E | Telephone | NR | Adjusted mean 6.58 | Treatment effect=0.40 (−0.05–0.84)
Bell 2005^13^ RCT GOS-E
Bell 2005^13^ RCT GOS-E | Standard | NR | Adjusted mean 6.19
Bell 2005^13^ RCT PQoL | Telephone | NR | Adjusted mean 78.9 | Treatment effect=8.8 (1.7–15.9)
Bell 2005^13^ RCT PQoL
Bell 2005^13^ RCT PQoL | Standard | NR | Adjusted mean 70.1
Cicerone 2004 11 QCI | Intensive Cognitive Rehabilitation Program (ICRP) (n=34) | NR | 27.1 (4.6) | Standard treatment group reported higher QCI scores (P<.01)
Cicerone 2004 11 QCI
Cicerone 2004 11 QCI | Standard Neurorehabilitation Program (STD) (n=34) | NR | 29.7 (4.4)
Thomas 2004 15 | Potential Unlimited Program | 35.36 (8.80) | Stage 1 42.57 (11.08) Posttreatment 38.26 (10.56) 6-month followup 46.14 (12.22) 2-year followup 50.00 (13.95) | Only significant difference between groups at 6-month followup.
Thomas 2004 15
Thomas 2004 15 | No treatment | 38.63 (21.97) | Stage 1 39.63 (19.66) Posttreatment 39.00 (18.88) 6-month followup 20.25 (14.73) 2-year followup 41.83 (10.36)
Semlyen 1998^16^ quasi-experimental (CCT) [underlined: Newcastle Independence Assessment Form (NIAF)] 6–12 months post treatment (rehab period) | Multidisciplinary rehabilitation service (n=33) | Group differences in change 8 wk to 12 wk 4.00 (p<0.001)^†^ | Group differences in change 6 mo to 12 mo 3.82 (p<0.01)^†^ | The multidisciplinary rehabilitation service group showed significant gains throughout the rehabilitation period, the single discipline approach group did not.
Semlyen 1998^16^ quasi-experimental (CCT) [underlined: Newcastle Independence Assessment Form (NIAF)] 6–12 months post treatment (rehab period)
Semlyen 1998^16^ quasi-experimental (CCT) [underlined: Newcastle Independence Assessment Form (NIAF)] 6–12 months post treatment (rehab period) | Single discipline approach (n=18) | Group differences in change 8 wk to 12 wk 2.30 (p<0.05)^†^ | Group differences in change 6 mo to 12 mo 1.05 (p NS)
Greenwood 1994^4^ GOS-E | Case-management (N=53 at entry) | NR | 6 months posttreatment 5.3 (1.7) N=48 12 months posttreatment 5.5 (1.6) N=37 24 months posttreatment 5.6 (1.5) N=21 | No group differences.
Greenwood 1994^4^ GOS-E
Greenwood 1994^4^ GOS-E | Control (N=65 at entry) | NR | 6 months posttreatment 5.8 (1.5) N=59 12 months posttreatment 6.2 (1.4) N=55 24 months posttreatment 6.3 (1.2) N=29
Greenwood 1994^4^ GOS-E | Case-management (N=53 at entry) | NR | 24 months posttreatment 2.0 (2.4) N=19 | Case managed have significantly worse DRS scores. (p<0.05)
Greenwood 1994^4^ GOS-E
Greenwood 1994^4^ GOS-E | Control (N=65 at entry) | NR | 24 months posttreatment 0.6 (1.7) N=29

* Based on Cohen’s “Rules-of-Thumb” standardized mean difference effect size are as follows: small = 0.20; medium = 0.50; and large = 0.80.

** 25^th^ and 75^th^ quartiles.

† For within group differences between means at each time point

ES = effect size; NS = not statistically significant; RR = Risk ratio [95% confidence interval]

Note: This table presents the results of studies that assessed a secondary outcome.