# Excluded Studies

1 Altman IM, Swick S, Parrot D, et al. Effectiveness of community-based rehabilitation after traumatic brain injury for 489 program completers compared with those precipitously discharged. Archives of Physical Medicine & Rehabilitation. Nov. 2010;91(11):1697-704. Not eligible study design. [pmid: 21044714].
2 Anderson SI, Wilson CL, McDowell IP, et al. Late rehabilitation for closed head injury: a follow-up study of patients 1 year from time of discharge. Brain Injury. Feb. 1996;10(2):115-24. No comparison group. [pmid: 8696311].
3 Ashley MJ, Persel CS, Clark MC, et al. Long-term follow-up of post-acute traumatic brain injury rehabilitation: a statistical analysis to test for stability and predictability of outcome. Brain Injury. Sep. 1997;11(9):677-90. Not intervention study. [pmid: 9376835].
4 Ashley MJ, Persel CS, Lehr RP Jr, et al. Post-acute rehabilitation outcome: relationship to case-management techniques and strategy. Journal of Insurance Medicine (Seattle). 1994;26(3):348-54. Not eligible study design. [pmid: 10150511].
5 Backhaus SL, Ibarra SL, Klyce D, et al. Brain injury coping skills group: a preventative intervention for patients with brain injury and their caregivers. [Erratum appears in Arch Phys Med Rehabil. 2010 Nov;91(11):1793]. Archives of Physical Medicine & Rehabilitation. Jun. 2010;91(6):840-8. No primary or secondary outcomes. [pmid: 20510972].
6 Bateman A, Culpan FJ, Pickering AD, et al. The effect of aerobic training on rehabilitation outcomes after recent severe brain injury: a randomized controlled evaluation. Archives of Physical Medicine & Rehabilitation. Feb. 2001;82(2):174-82. No primary or secondary outcomes. [pmid: 11239307].
7 Bell KR, Brockway JA, Hart T, et al. Scheduled telephone intervention for traumatic brain injury: a multicenter randomized controlled trial. Archives of Physical Medicine & Rehabilitation. Oct. 2011;92(10):1552-60. Not 75% Moderate/Severe TBI. [pmid: 21963122].
8 Benge JF, Caroselli JS, Reed K, et al. Changes in supervision needs following participation in a residential post-acute brain injury rehabilitation programme. Brain Injury. 2010;24(6):844-50. Not eligible comparison group. [pmid: 20377342].
9 Bornhofen C, McDonald S. Comparing strategies for treating emotion perception deficits in traumatic brain injury. Journal of Head Trauma Rehabilitation. Mar–Apr. 2008;23(2):103-15. Impairment-specific intervention. [pmid: 18362764].
10 Bornhofen C, McDonald S. Treating deficits in emotion perception following traumatic brain injury. Neuropsychological Rehabilitation. Jan. 2008;18(1):22-44. Impairment-specific intervention. [pmid: 17852760].
11 Bourgeois MS, Lenius K, Turkstra L, et al. The effects of cognitive teletherapy on reported everyday memory behaviours of persons with chronic traumatic brain injury. Brain Injury. Nov. 2007;21(12):1245-57. Not 75% moderate/severe TBI. [pmid: 18236200].
12 Bowen A, Tennant A, Neumann V, et al. Neuropsychological rehabilitation for traumatic brain injury: do carers benefit?. Brain Injury. Jan. 2001;15(1):29-38. No primary or secondary outcomes. [pmid: 11201312].
13 Braunling-McMorrow D, Dollinger SJ, Gould M, et al. Outcomes of post-acute rehabilitation for persons with brain injury. Brain Injury. 2010;24(7–8):928-38. No comparison group. [pmid: 20545448].
14 Brooks N. The effectiveness of post-acute rehabilitation. Brain Injury. Apr–Jun. 1991;5(2):103-9. No original data. [pmid: 1873599].
15 Burke WH, Wesolowski MD, Guth ML. Comprehensive head injury rehabilitation: an outcome evaluation. Brain Injury. Oct–Dec. 1988;2(4):313-22. No comparison group. [pmid: 3203177].
16 Bush BA, Novack TA, Malec JF, et al. Validation of a model for evaluating outcome after traumatic brain injury. Archives of Physical Medicine & Rehabilitation. Dec. 2003;84(12):1803-7. No comparison group. [pmid: 14669187].
17 Cannon XL, Zhu WS, Poon Chetwyn CCCSW. Does Intensive Rehabilitation Improve Functional Outcome In Patients with Traumatic Brain Injury (TBI). Preliminary Results of a Prospective Randomized Controlled Trial. Journal of Neurotrauma. 1998;(1):85. No primary or secondary outcomes.
18 Carnevale GJ, Anselmi V, Busichio K, et al. Changes in ratings of caregiver burden following a community-based behavior management program for persons with traumatic brain injury. The Journal of head trauma rehabilitation. 2002;(2):83-95. Not 75% moderate/severe TBI. [pmid: 11909508].
19 Carnevale GJ, Anselmi V, Johnston MV, et al. A natural setting behavior management program for persons with acquired brain injury: a randomized controlled trial. Archives of physical medicine and rehabilitation. 2006;(10):1289-97. No primary or secondary outcomes. [pmid: 17023236].
20 Cattelani R, Roberti R, Lombardi F. Adverse effects of apathy and neurobehavioral deficits on the community integration of traumatic brain injury subjects. European journal of physical & rehabilitation medicine. Sep. 2008;44(3):245-51. Not intervention study. [pmid: 18762734].
21 Cattelani R, Tanzi F, Lombardi F, et al. Competitive re-employment after severe traumatic brain injury: clinical, cognitive and behavioural predictive variables. Brain Injury. Jan. 2002;16(1):51-64. Not intervention study. [pmid: 11796099].
22 Cattelani R, Zettin M, Zoccolotti P. Rehabilitation treatments for adults with behavioral and psychosocial disorders following acquired brain injury: a systematic review. Neuropsychology Review. Mar. 2010;20(1):52-85. No original data. [pmid: 20143264].
23 Chang Zj LP. Rehabilitation and acupuncture treatment for patients with traumatic brain injury. Chinese Journal of Medical Device. 2005;(5):38-9. No primary or secondary outcomes.
24 Chard SE. Community neurorehabilitation: a synthesis of current evidence and future research directions. NeuroRx. Oct. 2006;3(4):525-34. No original data. [pmid: 17012066].
25 Chen SH, Thomas JD, Glueckauf RL, et al. The effectiveness of computer-assisted cognitive rehabilitation for persons with traumatic brain injury. Brain Injury. Mar. 1997;11(3):197-209. No primary or secondary outcomes. [pmid: 9058001].
26 Chesnut RM, Carney N, Maynard H, et al. Summary report: evidence for the effectiveness of rehabilitation for persons with traumatic brain injury. The Journal of Head Trauma Rehabilitation. 1999;14(2):176-188. 1999. No original data. [pmid: 10191375].
27 Choi JH, Jakob M, Stapf C, et al. Multimodal early rehabilitation and predictors of outcome in survivors of severe traumatic brain injury. Journal of Trauma-Injury Infection & Critical Care. Nov. 2008;65(5):1028-35. 1900. 1970. No comparison group.
28 Cicerone KD, Azulay J, Trott C. Methodological quality of research on cognitive rehabilitation after traumatic brain injury. Archives of Physical Medicine & Rehabilitation. Nov. 2009;90(11 Suppl):S52-9. No original data. [pmid: 19892075].
29 Cicerone KD, Dahlberg C, Kalmar K, et al. Evidence-based cognitive rehabilitation: recommendations for clinical practice. Archives of Physical Medicine & Rehabilitation. Dec. 2000;81(12):1596-615. No original data. [pmid: 11128897].
30 Cicerone KD, Dahlberg C, Malec JF, et al. Evidence-based cognitive rehabilitation: updated review of the literature from 1998 through 2002. Archives of Physical Medicine & Rehabilitation. Aug. 2005;86(8):1681-92. No original data. [pmid: 16084827].
31 Cicerone KD, Langenbahn DM, Braden C, et al. Evidence-based cognitive rehabilitation: updated review of the literature from 2003 through 2008. Archives of Physical Medicine & Rehabilitation. Apr. 2011;92(4):519-30. No original data. [pmid: 21440699].
32 Cifu DX, Kreutzer JS, Kolakowsky-Hayner SA, et al. The relationship between therapy intensity and rehabilitative outcomes after traumatic brain injury: a multicenter analysis. Archives of Physical Medicine & Rehabilitation. Oct. 2003;84(10):1441-8. No primary or secondary outcomes. [pmid: 14586910].
33 Coetzer R, Rushe R. Post-acute rehabilitation following traumatic brain injury: are both early and later improved outcomes possible?. International Journal of Rehabilitation Research. Dec. 2005;28(4):361-3. No comparison group. [pmid: 16319563].
34 Constantinidou F, Thomas RD, Robinson L. Benefits of categorization training in patients with traumatic brain injury during post-acute rehabilitation: additional evidence from a randomized controlled trial. Journal of Head Trauma Rehabilitation. Sep–Oct. 2008;23(5):312-28. Impairment-specific intervention. [pmid: 18815508].
35 Cope DN, Cole JR, Hall KM, et al. Brain injury: analysis of outcome in a post-acute rehabilitation system. Part 2: Subanalyses. Brain Injury. Apr–Jun. 1991;5(2):127-39. No comparison group. [pmid: 1908341].
36 Cope DN, Cole JR, Hall KM, et al. Brain injury: analysis of outcome in a post-acute rehabilitation system. Part 1: General analysis. Brain Injury. Apr–Jun. 1991;5(2):111-25. No comparison group. [pmid: 1873600].
37 Cusick CP, Gerhart KA, Mellick D, et al. Evaluation of the home and community-based services brain injury Medicaid Waiver Programme in Colorado. Brain Injury. Nov. 2003;17(11):931-45. Not eligible study design. [pmid: 14514446].
38 Dahlberg CA, Cusick CP, Hawley LA, et al. Treatment efficacy of social communication skills training after traumatic brain injury: a randomized treatment and deferred treatment controlled trial. Archives of Physical Medicine & Rehabilitation. Dec. 2007;88(12):1561-73. Impairment-specific intervention. [pmid: 18047870].
39 Dawson DR. A multidsciplinary community-based rehabilitation program improved social functioning in severe traumatic brain injury. ACP Journal Club. 2002;(1):22. No original data. [pmid: 12093221].
40 Devitt R, Colantonio A, Dawson D, et al. Prediction of long-term occupational performance outcomes for adults after moderate to severe traumatic brain injury. Disability & Rehabilitation. May. 15. 2006;28(9):547-59. Not intervention study. [pmid: 16690584].
41 Dirette DK, Hinojosa J, Carnevale GJ. Comparison of remedial and compensatory interventions for adults with acquired brain injuries. Journal of Head Trauma Rehabilitation. Dec. 1999;14(6):595-601. Not 75% moderate/severe TBI. [pmid: 10671705].
42 Do HK, Sahagian DA, Schuster LC, et al. Head trauma rehabilitation: program evaluation. Rehabilitation Nursing. Mar–Apr. 1988;13(2):71-5. No primary or secondary outcome. [pmid: 3353569].
43 Doig E, Fleming J, Tooth L. Patterns of community integration 2–5 years post-discharge from brain injury rehabilitation. Brain Injury. Sep. 2001;15(9):747-62. Not intervention study. [pmid: 11516344].
44 Drechsler R, Padovan F, Di Stefano G, et al. An integrated concept for vocational rehabilitation of brain injured patients--a catamnestic study of occupational outcome 1 to 2 years later. Rehabilitation. Nov. 1995;34(4):193-202. No comparison group. [pmid: 8570901].
45 Eames P, Cotterill G, Kneale TA, et al. Outcome of intensive rehabilitation after severe brain injury: a long-term follow-up study. Brain Injury. Sep. 1996;10(9):631-50. No comparison group. [pmid: 8853867].
46 Eicher V, Murphy MP, Murphy TF, et al. Progress assessed with the mayo-portland adaptability inventory in 604 participants in 4 types of post-inpatient rehabilitation brain injury programs. Archives of Physical Medicine & Rehabilitation. Jan. 2012;93(1):100-7. Retrospective Study. [pmid: 22200388].
47 Evans L, Brewis C. New Zealand Guidelines Group NZACC. The efficacy of community-based rehabilitation programmes for adults with TBI [with consumer summary]. International Journal of Therapy and Rehabilitation. Oct. 2008;15(10):446-458. 2008. No original data.
48 Felmingham KL, Baguley IJ, Crooks J. A comparison of acute and postdischarge predictors of employment 2 years after traumatic brain injury. Archives of Physical Medicine & Rehabilitation. Apr. 2001;82(4):435-9. No comparison group. [pmid: 11295001].
49 Fleming J, Kuipers P, Foster M, et al. Evaluation of an outpatient, peer group intervention for people with acquired brain injury based on the ICF ‘environment’ dimension. Disability and Rehabilitation: An International, Multidisciplinary Journal. 2009;31(20). pp. Peer Reviewed Journal: 2010-12838-005. Not 75% moderate/severe TBI.
50 Fleming JM, Lucas SE, Lightbody S. Using occupation to facilitate self-awareness in people who have acquired brain injury: A pilot study. Canadian Journal of Occupational Therapy/Revue Canadienne D’Ergotherapie. 2006;73(1). pp. Peer Reviewed Journal: 2008-00032-005. Not intervention study.
51 Fleming JM, Strong J, Ashton R. Cluster analysis of self-awareness levels in adults with traumatic brain injury and relationshipto outcome. Journal of Head Trauma Rehabilitation. Oct. 1998;13(5):39-51. No comparison group. [pmid: 9753534].
52 Frankel JE, Marwitz JH, Cifu DX, et al. A follow-up study of older adults with traumatic brain injury: taking into account decreasing length of stay. Archives of Physical Medicine & Rehabilitation. Jan. 2006;87(1):57-62. Not eligible study design. [pmid: 16401439].
53 Geurtsen G, Martina J, Van Heugten C, et al. A prospective study to evaluate a new residential community reintegration programme for severe chronic brain injury: The Brain Integration Programme. Brain Injury. 2008;22:7-8. pp. Peer Reviewed Journal: 2008-09277-005. No comparison group. [pmid: 18183504].
54 Geurtsen GJ, van Heugten CM, Martina JD, et al. A prospective study to evaluate a residential community reintegration program for patients with chronic acquired brain injury. Archives of Physical Medicine & Rehabilitation. May. 2011;92(5):696-704. Not 75% moderate/severe TBI. [pmid: 21530716].
55 Giles GM. Cognitive versus functional approaches to rehabilitation after traumatic brain injury: commentary on a randomized controlled trial. American Journal of Occupational Therapy. 2010;(1):182-5. No original data. [pmid: 20131578].
56 Goranson TE, Graves RE, Allison D, et al. Community integration following multidisciplinary rehabilitation for traumatic brain injury. Brain Injury. Sep. 2003;17(9):759-74. Not 75% moderate/severe TBI. [pmid: 12850942].
57 Gray DS, Burnham RS. Preliminary outcome analysis of a long-term rehabilitation program for severe acquired brain injury. Archives of Physical Medicine & Rehabilitation. Nov. 2000;81(11):1447-56. Not intervention study. [pmid: 11083347].
58 Greenwood RJ, Strens LHA, Watkin J, et al. A study of acute rehabilitation after head injury. British Journal of Neurosurgery. Oct. 2004;18(5):462-6. Not eligible study design. [pmid: 15799146].
59 Grill E, Ewert T, Lipp B, et al. Effectiveness of a community-based 3-year advisory program after acquired brain injury. European Journal of Neurology. Nov. 2007;14(11):1256-65. Not eligible study design. [pmid: 17956446].
60 Groswasser Z, Melamed S, Agranov E, et al. Return to work as an integrative outcome measure following traumatic brain injury. Neuropsychological Rehabilitation. 1999;9:3-4. pp. Peer Reviewed Journal: 1999-01087-020. No comparison group.
61 Groswasser Z, Sazbon L. Outcome in 134 patients with prolonged posttraumatic unawareness. Part 2: Functional outcome of 72 patients recovering consciousness. Journal of Neurosurgery. Jan. 1990;72(1):81-4. No comparison group. [pmid: 2294189].
62 Gurka JA, Felmingham KL, Baguley IJ, et al. Utility of the functional assessment measure after discharge from inpatient rehabilitation. Journal of Head Trauma Rehabilitation. Jun. 1999;14(3):247-56. No comparison group. [pmid: 10381977].
63 Harradine PG, Winstanley JB, Tate R, et al. Severe traumatic brain injury in New South Wales: comparable outcomes for rural and urban residents. Medical Journal of Australia. Aug. 2. 2004;181(3):130-4. No comparison group. [pmid: 15287829].
64 Harrick L, Krefting L, Johnston J, et al. Stability of functional outcomes following transitional living programme participation: 3-year follow-up. Brain Injury. Jul. 1994;8(5):439-47. No comparison group. [pmid: 7951206].
65 Hart T, Hawkey K, Whyte J. Use of a portable voice organizer to remember therapy goals in traumatic brain injury rehabilitation: a within-subjects trial. Journal of Head Trauma Rehabilitation. Dec. 2002;17(6):556-70. No primary or secondary outcomes. [pmid: 12802246].
66 Hassan N, Turner-Stokes L, Pierce K, et al. A completed audit cycle and integrated care pathway for the management of depression following brain injury in a rehabilitation setting. Clinical Rehabilitation. Aug. 2002;16(5):534-40. No comparison group. [pmid: 12194624].
67 Hawkins ML, Lewis FD, Medeiros RS. Serious traumatic brain injury: an evaluation of functional outcomes. Journal of Trauma-Injury Infection & Critical Care. Aug. 1996;41(2):257-63. discussion 63–4. No comparison group. [pmid: 8760533].
68 Hawley LANJK. Group interactive structured treatment (GIST): A social competence intervention for individuals with brain injury. Brain Injury. 2010;(11):1292-7. No original data. [pmid: 20735320].
69 Hermens H, Huijgen B, Giacomozzi C, et al. Clinical assessment of the HELLODOC tele-rehabilitation service. Annali Dell’Istituto Superiore di Sanita. 2008;44(2):154-63. No comparison group. [pmid: 18660565].
70 High WM Jr, Roebuck-Spencer T, Sander AM, et al. Early versus later admission to postacute rehabilitation: impact on functional outcome after traumatic brain injury. Archives of Physical Medicine & Rehabilitation. Mar. 2006;87(3):334-42. Not eligible comparison group. [pmid: 16500166].
71 Hoofien D, Gilboa A, Vakil E, et al. Traumatic brain injury (TBI) 10–20 years later: a comprehensive outcome study of psychiatric symptomatology, cognitive abilities and psychosocial functioning. Brain Injury. Mar. 2001;15(3):189-209. Not intervention study. [pmid: 11260769].
72 Houlden H, Edwards M, McNeil J, et al. Use of the Barthel Index and the Functional Independence Measure during early inpatient rehabilitation after single incident brain injury. Clinical Rehabilitation. Feb. 2006;20(2):153-9. Not intervention study. [pmid: 16541936].
73 Jellinek HM, Harvey RF. Vocational/educational services in a medical rehabilitation facility: outcomes in spinal cord and brain injured patients. Archives of Physical Medicine & Rehabilitation. Feb. 1982;63(2):87-8. Not intervention study. [pmid: 7059275].
74 Jellinek HM, Torkelson RM, Harvey RF. Functional abilities and distress levels in brain injured patients at long-term follow-up. Archives of Physical Medicine & Rehabilitation. Apr. 1982;63(4):160-2. Not eligible study design. [pmid: 7082138].
75 Johnston MV. Outcomes of community re-entry programmes for brain injury survivors. Part 2: Further investigations. Brain Injury. Apr–Jun. 1991;5(2):155-68. Not eligible study design. [pmid: 1651796].
76 Kashluba S, Hanks RA, Casey JE, et al. Neuropsychologic and functional outcome after complicated mild traumatic brain injury. Archives of Physical Medicine & Rehabilitation. May. 2008;89(5):904-11. Not 75% moderate/severe TBI. [pmid: 18452740].
77 Katz DI, White DK, Alexander MP, et al. Recovery of ambulation after traumatic brain injury. Archives of Physical Medicine & Rehabilitation. Jun. 2004;85(6):865-9. Not intervention study. [pmid: 15179637].
78 Khan F, Baguley IJ, Cameron ID. 4: Rehabilitation after traumatic brain injury. Medical Journal of Australia. Mar. 17. 2003;178(6):290-5. Not intervention study. [pmid: 12633489].
79 Khan S, Khan A, Feyz M. Decreased Length of stay, cost savings and descriptive findings of enhanced patient care resulting from and integrated traumatic brain injury programme. Brain Injury. Jun. 2002;16(6):537-54. Not eligible study design. [pmid: 12148505].
80 Klonoff PS, Lamb DG, Henderson SW. Milieu-based neurorehabilitation in patients with traumatic brain injury: outcome at up to 11 years postdischarge. Archives of Physical Medicine & Rehabilitation. Nov. 2000;81(11):1535-7. No comparison group. [pmid: 11083362].
81 Klonoff PS, Lamb DG, Henderson SW. Outcomes from milieu-based neurorehabilitation at up to 11 years post-discharge. Brain Injury. May. 2001;15(5):413-28. No comparison group. [pmid: 11350655].
82 Kreutzer JS, Rapport LJ, Marwitz JH, et al. Caregivers’ well-being after traumatic brain injury: a multicenter prospective investigation. Archives of Physical Medicine & Rehabilitation. Jun. 2009;90(6):939-46. No comparison group. [pmid: 19480869].
83 Leon-Carrion J, Dominguez-Morales MR, Martin JMBY. Driving with cognitive deficits: neurorehabilitation and legal measures are needed for driving again after severe traumatic brain injury. Brain Injury. Mar. 2005;19(3):213-9. No comparison group. [pmid: 15832895].
84 Lipper-Gruner M, Wedekind C, Klug N. Functional and psychosocial outcome one year after severe traumatic brain injury and early-onset rehabilitation therapy. Journal of Rehabilitation Medicine. Sep. 2002;34(5):211-4. No comparison group. [pmid: 12392235].
85 Lippert-Gruner M. Early rehabilitation of comatose patients after traumatic brain injury. Neurologia i Neurochirurgia Polska. Sep–Oct. 2010;44(5):475-80. No comparison group. [pmid: 21082492].
86 Lippert-Gruner M, Lefering R, Svestkova O. Functional outcome at 1 vs. 2 years after severe traumatic brain injury. Brain Injury. Sep. 2007;21(10):1001-5. Not intervention study. [pmid: 17891561].
87 Lippert-Gruner M, Wedekind C, Klug N. Outcome of prolonged coma following severe traumatic brain injury. Brain Injury. Jan. 2003;17(1):49-54. No comparison group. [pmid: 12519647].
88 Livingston MG, Brooks DN, Bond MR. Patient outcome in the year following severe head injury and relatives’ psychiatric and social functioning. Journal of Neurology, Neurosurgery & Psychiatry. Sep. 1985;48(9):876-81. Not intervention study. [pmid: 4045482].
89 Loney TG. The relationship between physical and occupational therapy intensity and rehabilitation outcomes of traumatic brain injury: A comparison of war wounded to non-war wounded persons. 2008 Dissertation. Abstract: 2008-99120-260. Not eligible study design.
90 Malec JF, Moessner AM. Self-awareness, distress, and postacute rehabilitation outcome. Rehabilitation Psychology. 2000;45(3). pp. Peer Reviewed Journal: 2000-15971-001. No comparison group.
91 Malec JF, Moessner AM. Replicated positive results for the VCC model of vocational intervention after ABI within the social model of disability. Brain Injury. Mar. 2006;20(3):227-36. No comparison group. [pmid: 16537264].
92 Malec JF, Smigielski JS, DePompolo RW, et al. Outcome evaluation and prediction in a comprehensive-integrated post-acute outpatient brain injury rehabilitation programme. Brain Injury. Jan–Feb. 1993;7(1):15-29. No comparison group. [pmid: 8425113].
93 Matsushima Y, Ueda M, Saeki S, et al. Outcome of rehabilitation for traumatic brain injury in the UOEH Hospital. Journal of Uoeh. Dec. 1. 2001;23(4):451-6. Not intervention study. [pmid: 11789148].
94 McDonald S, Tate R, Togher L, et al. Social skills treatment for people with severe, chronic acquired brain injuries: a multicenter trial. Archives of physical medicine and rehabilitation. 2008;(9):1648-59. Impairment-specific intervention. [pmid: 18760150].
95 McLaughlin AM, Peters S. Evaluation of an innovative cost-effective programme for brain injury patients: response to a need for flexible treatment planning. Brain Injury. Jan–Feb. 1993;7(1):71-5. Not eligible study design. [pmid: 8425118].
96 McPherson KM, Kayes N, Weatherall M, et al. A pilot study of self-regulation informed goal setting in people with traumatic brain injury. Clinical Rehabilitation. Apr. 2009;23(4):296-309. No primary or secondary outcomes. [pmid: 19293290].
97 Merritta C, Cherian B, Macaden AS, et al. Measurement of physical performance and objective fatigability in people with mild-to-moderate traumatic brain injury. International Journal of Rehabilitation Research. Jun. 2010;33(2):109-14. No primary or secondary outcomes. [pmid: 19593157].
98 Mills VM, Nesbeda T, Katz DI, et al. Outcomes for traumatically brain-injured patients following post-acute rehabilitation programmes. Brain Injury. May–Jun. 1992;6(3):219-28. No comparison group. [pmid: 1581745].
99 Murphy L, Chamberlain E, Weir J, et al. Effectiveness of vocational rehabilitation following acquired brain injury: preliminary evaluation of a UK specialist rehabilitation programme. Brain Injury. Oct. 2006;20(11):1119-29. No comparison group. [pmid: 17123928].
100 Murrey GJ, Starzinski D. An inpatient neurobehavioural rehabilitation programme for persons with traumatic brain injury: overview of and outcome data for the Minnesota Neurorehabilitation Hospital. Brain Injury. Jun. 2004;18(6):519-31. No comparison group. [pmid: 15204334].
101 Neistadt ME. Occupational therapy treatments for constructional deficits. American Journal of Occupational Therapy. Feb. 1992;46(2):141-8. No primary or secondary outcomes. [pmid: 1595825].
102 Ng YS, Chua KSG. States of severely altered consciousness: clinical characteristics, medical complications and functional outcome after rehabilitation. Neurorehabilitation. 2005;20(2):97-105. Not intervention study. [pmid: 15920302].
103 Niemeier JP, Kreutzer JS, Marwitz JH, et al. Efficacy of a brief acute neurobehavioural intervention following traumatic brain injury: a preliminary investigation. Brain Injury. 2011;25(7–8):680-90. Not 75% Moderate/Severe TBI. [pmid: 21604926].
104 Noe E, Ferri J, Caballero MC, et al. Self-awareness after acquired brain injury--predictors and rehabilitation. Journal of Neurology. Feb. 2005;252(2):168-75. No primary or secondary outcomes. [pmid: 15729522].
105 Olver JH, Ponsford JL, Curran CA. Outcome following traumatic brain injury: a comparison between 2 and 5 years after injury. Brain Injury. Nov. 1996;10(11):841-8. No comparison group. [pmid: 8905161].
106 Ownsworth T, Desbois J, Grant E, et al. The associations among self-awareness, emotional well-being, and employment outcome following acquired brain injury: A 12-month longitudinal study. Rehabilitation Psychology. 2006;51(1). pp. Peer Reviewed Journal: 2006-02509-007. No comparison group.
107 Ownsworth T, Fleming J, Shum D, et al. Comparison of individual, group and combined intervention formats in a randomized controlled trial for facilitating goal attainment and improving psychosocial function following acquired brain injury. Journal of Rehabilitation Medicine. Feb. 2008;40(2):81-8. No comparison group. [pmid: 18509570].
108 Pace GM, Schlund MW, Hazard-Haupt T, et al. Characteristics and outcomes of a home and community-based neurorehabilitation programme. Brain Injury. Jul. 1999;13(7):535-46. No comparison group. [pmid: 10462150].
109 Paniak C, Toller-Lobe G, Durand A, et al. A randomized trial of two treatments for mild traumatic brain injury. Brain Injury. 1998;12(12):1011-23. Not 75% moderate/severe TBI. [pmid: 9876861].
110 Parente R, Stapleton M. Development of a cognitive strategies group for vocational training after traumatic brain injury. Neurorehabilitation. 1999;13(1):13-20. Not 75% moderate/severe TBI.
111 Peters MD, Gluck M, McCormick M. Behaviour rehabilitation of the challenging client in less restrictive settings. Brain Injury. Jul–Aug. 1992;6(4):299-314. No comparison group. [pmid: 1638264].
112 Prigatano GP, Wong JL. Cognitive and affective improvement in brain dysfunctional patients who achieve inpatient rehabilitation goals. Archives of Physical Medicine & Rehabilitation. Jan. 1999;80(1):77-84. No primary or secondary outcomes. [pmid: 9915376].
113 Rath JF, Simon D, Langenbahn DM, et al. Group treatment of problem-solving deficits in outpatients with traumatic brain injury: a randomised outcome study. Neuropsychological Rehabilitation. 2003;(4):461-88. No primary or secondary outcomes.
114 Rollnik JD, Allmann J. Occupational rehabilitation of neurological patients - long-term outcome data. Rehabilitation. Feb. 2011;50(1):37-43. No comparison group. [pmid: 21321823].
115 Ruff RM, Niemann H. Cognitive rehabilitation versus day treatment in head-injured adults: is there an impact on emotional and psychosocial adjustment?. Brain Injury. Oct–Dec. 1990;4(4):339-47. No primary or secondary outcomes. [pmid: 2252966].
116 Ryan TV, Ruff RM. The efficacy of structured memory retraining in a group comparison of head trauma patients. Archives of Clinical Neuropsychology. 1988;3(2):165-79. No primary or secondary outcomes. [pmid: 14591268].
117 Sander AM, Roebuck TM, Struchen MA, et al. Long-term maintenance of gains obtained in postacute rehabilitation by persons with traumatic brain injury. Journal of Head Trauma Rehabilitation. Aug. 2001;16(4):356-73. No comparison group. [pmid: 11461658].
118 Sayer NA, Chiros CE, Sigford B, et al. Characteristics and rehabilitation outcomes among patients with blast and other injuries sustained during the Global War on Terror. Archives of Physical Medicine & Rehabilitation. Jan. 2008;89(1):163-70. No comparison group. [pmid: 18164349].
119 Schalen W, Hansson L, Nordstrom G, et al. Psychosocial outcome 5–8 years after severe traumatic brain lesions and the impact of rehabilitation services. Brain Injury. Jan. 1994;8(1):49-64. Not eligible study design. [pmid: 8124317].
120 Schatz P, Hillary FG, Moelter ST, et al. Retrospective assessment of rehabilitation outcome after traumatic brain injury: development and utility of the functional independence level. Journal of Head Trauma Rehabilitation. Dec. 2002;17(6):510-25. Not eligible study design. [pmid: 12802242].
121 Scherzer BP. Rehabilitation following severe head trauma: results of a three-year program. Archives of Physical Medicine & Rehabilitation. Jun. 1986;67(6):366-74. No primary or secondary outcomes. [pmid: 3718196].
122 Schonberger M, Humle F, Teasdale TW. Subjective outcome of brain injury rehabilitation in relation to the therapeutic working alliance, client compliance and awareness. Brain Injury. Nov. 2006;20(12):1271-82. No comparison group. [pmid: 17132550].
123 Schonberger M, Humle F, Teasdale TW. The development of the therapeutic working alliance, patients’ awareness and their compliance during the process of brain injury rehabilitation. Brain Injury. Apr. 2006;20(4):445-54. No comparison group. [pmid: 16716990].
124 Schonberger M, Humle F, Teasdale TW. The relationship between clients’ cognitive functioning and the therapeutic working alliance in post-acute brain injury rehabilitation. Brain Injury. Jul. 2007;21(8):825-36. No comparison group. [pmid: 17676440].
125 Schonberger M, Humle F, Zeeman P, et al. Patient compliance in brain injury rehabilitation in relation to awareness and cognitive and physical improvement. Neuropsychological Rehabilitation. Oct. 2006;16(5):561-78. No comparison group. [pmid: 16952893].
126 Schwartz I, Tsenter J, Shochina M, et al. Rehabilitation outcomes of terror victims with multiple traumas. Archives of Physical Medicine & Rehabilitation. Apr. 2007;88(4):440-8. Not eligible comparison group. [pmid: 17398244].
127 Schwartz I, Tuchner M, Tsenter J, et al. Cognitive and functional outcomes of terror victims who suffered from traumatic brain injury. Brain Injury. Mar. 2008;22(3):255-63. Not eligible comparison group. [pmid: 18297597].
128 Seale GS, Caroselli JS, High WM Jr, et al. Use of community integration questionnaire (CIQ) to characterize changes in functioning for individuals with traumatic brain injury who participated in a post-acute rehabilitation programme. Brain Injury. Nov. 2002;16(11):955-67. Not eligible comparison group. [pmid: 12455520].
129 Seel RT, Wright G, Wallace T, et al. The utility of the FIM+FAM for assessing traumatic brain injury day program outcomes. Journal of Head Trauma Rehabilitation. Sep–Oct. 2007;22(5):267-77. Not eligible study design. [pmid: 17878768].
130 Sendroy-Terrill M, Whiteneck GG, Brooks CA. Aging with traumatic brain injury: cross-sectional follow-up of people receiving inpatient rehabilitation over more than 3 decades. Archives of Physical Medicine & Rehabilitation. Mar. 2010;91(3):489-97. Not intervention study. [pmid: 20298844].
131 Sherer M, Evans CC, Leverenz J, et al. Therapeutic alliance in post-acute brain injury rehabilitation: predictors of strength of alliance and impact of alliance on outcome. Brain Injury. Jun. 2007;21(7):663-72. No comparison group. [pmid: 17653940].
132 Shiel A, Burn JP, Henry D, et al. The effects of increased rehabilitation therapy after brain injury: results of a prospective controlled trial. Clinical Rehabilitation. Oct. 2001;15(5):501-14. No primary or secondary outcomes. [pmid: 11594640].
133 Shum D, Fleming J, Gill H, et al. A randomized controlled trial of prospective memory rehabilitation in adults with traumatic brain injury. Journal of Rehabilitation Medicine. Feb. 2011;43(3):216-23. Impairment-specific intervention. [pmid: 21305237].
134 Slade A, Tennant A, Chamberlain MA. A randomised controlled trial to determine the effect of intensity of therapy upon length of stay in a neurological rehabilitation setting. Journal of Rehabilitation Medicine. Nov. 2002;34(6):260-6. Not 75% moderate/severe TBI. [pmid: 12440799].
135 Smith MJ, Vaughan FL, Cox LJ, et al. The impact of community rehabilitation for acquired brain injury on carer burden: an exploratory study. Journal of Head Trauma Rehabilitation. Jan–Feb. 2006;21(1):76-81. Not intervention study. [pmid: 16456394].
136 Sorbo A, Rydenhag B, Sunnerhagen KS, et al. Outcome after severe brain damage, what makes the difference?. Brain Injury. Jul. 2005;19(7):493-503. No comparison group. [pmid: 16134737].
137 Spikman JM, Boelen DHE, Lamberts KF, et al. Effects of a multifaceted treatment program for executive dysfunction after acquired brain injury on indications of executive functioning in daily life. Journal of the International Neuropsychological Society. Jan. 2010;16(1):118-29. Not 75% moderate/severe TBI. [pmid: 19900348].
138 Struchen MA, Clark AN, Sander AM, et al. Relation of executive functioning and social communication measures to functional outcomes following traumatic brain injury. Neurorehabilitation. 2008;23(2):185-98. Not intervention study. [pmid: 18525140].
139 Struchen MA, Davis LC, Bogaards JA, et al. Making connections after brain injury: development and evaluation of a social peer-mentoring program for persons with traumatic brain injury. The Journal of head trauma rehabilitation. 2011;(1):4-19. Impairment-specific intervention. [pmid: 21209559].
140 Switzer SF, Hinebaugh FL. Outcome results of post-acute rehabilitation after head injury. Five consecutive studies of 198 individuals over a five-year period. Journal of Insurance Medicine (Seattle). 1991;23(4):239-44. Not eligible study design. [pmid: 10148507].
141 Teasdale TW, Christensen AL, Pinner EM. Psychosocial rehabilitation of cranial trauma and stroke patients. Brain Injury. Nov–Dec. 1993;7(6):535-42. No comparison group. [pmid: 8260957].
142 Tiersky LA, Anselmi V, Johnston MV, et al. A trial of neuropsychologic rehabilitation in mild-spectrum traumatic brain injury. Archives of Physical Medicine & Rehabilitation. Aug. 2005;86(8):1565-74. Not 75% moderate/severe TBI. [pmid: 16084809].
143 Tobis JS, Puri KB, Sheridan J. Rehabilitation of the severely brain-injured patient. Scandinavian Journal of Rehabilitation Medicine. 1982;14(2):83-8. No comparison group. [pmid: 7100833].
144 Tomaszewski W, Manko G. An evaluation of the strategic approach to the rehabilitation of traumatic brain injury (TBI) patients. Medical Science Monitor. Sep. 2011;17(9):CR510-6. No primary or secondary outcomes. [pmid: 21873948].
145 Trexler LE, Trexler LC, Malec JF, et al. Prospective randomized controlled trial of resource facilitation on community participation and vocational outcome following brain injury. The Journal of Head Trauma Rehabilitation. 2010;25(6). pp. Peer Reviewed Journal: 2010-23851-005. Not 75% moderate/severe TBI.
146 Trombly CA, Radomski MV, Trexel C, et al. Occupational therapy and achievement of self-identified goals by adults with acquired brain injury: phase II. American Journal of Occupational Therapy. Sep–Oct. 2002;56(5):489-98. Not 75% moderate/severe TBI. [pmid: 12269503].
147 Tuel SM, Presty SK, Meythaler JM, et al. Functional improvement in severe head injury after readmission for rehabilitation. Brain Injury. Jul–Aug. 1992;6(4):363-72. No comparison group. [pmid: 1638270].
148 Turner-Stokes L, Disler PB, Nair A, et al. Multi-disciplinary rehabilitation for acquired brain injury in adults of working age. Cochrane Database of Systematic Reviews. 2005;(3):CD004170. No original data. [pmid: 16034923].
149 Turner-Stokes L, Paul S, Williams H. Efficiency of specialist rehabilitation in reducing dependency and costs of continuing care for adults with complex acquired brain injuries. Journal of Neurology, Neurosurgery & Psychiatry. May. 2006;77(5):634-9. No comparison group. [pmid: 16614023].
150 Wade DT, Crawford S, Wenden FJ, et al. Does routine follow up after head injury help? A randomised controlled trial. Journal of Neurology, Neurosurgery & Psychiatry. May. 1997;62(5):478-84. Not 75% moderate/severe TBI. [pmid: 9153604].
151 Wade DT, King NS, Wenden FJ, et al. Routine follow up after head injury: a second randomised controlled trial. Journal of Neurology, Neurosurgery & Psychiatry. Aug. 1998;65(2):177-83. Not 75% moderate/severe TBI. [pmid: 9703167].
152 Waehrens EE, Fisher AG. Improving quality of ADL performance after rehabilitation among people with acquired brain injury. Scandinavian Journal of Occupational Therapy. Dec. 2007;14(4):250-7. No comparison group. [pmid: 17852966].
153 Walker WC, Marwitz JH, Kreutzer JS, et al. Occupational categories and return to work after traumatic brain injury: a multicenter study. Archives of Physical Medicine & Rehabilitation. Dec. 2006;87(12):1576-82. No comparison group. [pmid: 17141636].
154 Wehman P, Kregel J, Sherron P, et al. Critical factors associated with the successful supported employment placement of patients with severe traumatic brain injury. Brain Injury. Jan–Feb. 1993;7(1):31-44. No comparison group. [pmid: 8425114].
155 Wilson FC, Wheatley-Smith L, Downes C. Analysis of intensive outpatient neurorehabilitation outcomes using FIM+FAM(UK). Neurorehabilitation. 2009;24(4):377-82. No comparison group. [pmid: 19597276].
156 Wood RL, McCrea JD, Wood LM, et al. Clinical and cost effectiveness of post-acute neurobehavioural rehabilitation. Brain Injury. Feb. 1999;13(2):69-88. No comparison group. [pmid: 10079953].
157 Worthington AD, Matthews S, Melia Y, et al. Cost-benefits associated with social outcome from neurobehavioural rehabilitation. Brain Injury. Aug. 2006;20(9):947-57. No comparison group. [pmid: 17062426].
158 Yap SGM, Chua KSG. Rehabilitation outcomes in elderly patients with traumatic brain injury in Singapore. Journal of Head Trauma Rehabilitation. May–Jun. 2008;23(3):158-63. Not intervention study. [pmid: 18520428].
159 Yip BC, Man DW. Virtual reality (VR)-based community living skills training for people with acquired brain injury: A pilot study. Brain Injury. 2009;23:13-14. pp. Peer Reviewed Journal: 2009-21875-004. No comparison group.
160 Zampolini M, Franceschini M. Rehabilitation of traumatic brain injury in Italy. American Journal of Physical Medicine & Rehabilitation. Jan. 2011;90(1):79-82. No original data. [pmid: 21169748].
161 Zhu XL, Poon WS, Chan C, et al. Does Intensive Rehabilitation Improve the Functional Outcome of Patients with Traumatic Brain Injury (TBI)? Cognitive Function Result of a Randomised Controlled Trial. Acta Neurochirurgica - Supplementum. 2001. No primary or secondary outcomes.
162 Zhu XL, Poon WS, Chan CCH, et al. Does intensive rehabilitation improve the functional outcome of patients with traumatic brain injury (TBI)? A randomized controlled trial. Brain Injury. Jun. 2007;21(7):681-90. No primary or secondary outcomes. [pmid: 17653942].
163 Zhu XL, Poon WS, Chan CH, et al. Does intensive rehabilitation improve the functional outcome of patients with traumatic brain injury? Interim result of a randomized controlled trial. British Journal of Neurosurgery. Dec. 2001;15(6):464-73. No primary or secondary outcomes. [pmid: 11813997].
164 Zhu XL, Poon WS, Wai S, et al. Does intensive rehabilitation improve the functional outcome of patients with traumatic brain injury (TBI)? Result of a randomized controlled trial. Recent advances in neurotraumatology. 1999. No primary or secondary outcomes.