# Risk of Bias

Appendix B. Table 1 Risk of Bias for Individual Studies

Study | Study design | Overall Risk of Bias Assessment | Comments
Cicerone, 2008^1^ | RCT | Moderate | Possible contamination via same professionals delivering treatment and control interventions; minimally clinically important difference in CIQ not specified a priori; subjective self-report scale used for primary outcome measurement; no adjustment for multiple comparisons.
Vanderploeg, 2008^2^ | RCT | Low | Well-designed study; no adjustment for multiple comparisons.
Salazar, 2000^3^ | RCT | Moderate | Outcome assessors not blinded; intervention implementation judged partially adequate; primary outcomes self-report; no adjustment for multiple comparisons.
Greenwood, 1994^4^ | RCT | Moderate | Group randomization; moderate attrition at 6-month time point, high attrition at 12-month time point; no adjustment for multiple comparisons. Outcomes at 24 months considered high risk of bias due to high attrition and not used.
Ponsford, 2006^5^ | Cohort | High | Potential selection bias, retrospective control group; intervention definition and implementation partially adequate; no adjustment for multiple comparisons, many outcomes assessed including several scales and subscales; potential reporting bias.
Sarajuuri, 2005^6^ | Cohort | Moderate | Potential selection bias; confounding not appropriately addressed.
Prigatano, 1994^7^ | Cohort | High | Potential selection bias, retrospective control group; outcome assessors not blinded; intervention implementation partially adequate; inconsistent outcomes measurement across groups; confounding not adequately addressed.
Rattok, 1992^8^ | Cohort | Moderate | Possible contamination via same professionals delivering treatment and control interventions; blinding of outcomes assessors not reported; no adjustment for multiple comparisons.
Prigatano, 1984^9^ | Cohort | Moderate | Potential selection bias, retrospective control group; inadequate intervention implementation; inconsistent outcomes measurement across groups; confounding not adequately addressed.
Hashimoto, 2006^10^ | Cohort | High | Potential selection bias; blinding of outcomes assessors not reported, inadequate intervention definition; treatment group provided varying levels of treatment intensity, but comparisons are for entire group to a no treatment group; subjective self-report scale used for primary outcome measurement; minimally clinically important difference in CIQ not specified a priori; confounding not adequately addressed; no adjustment for multiple comparisons, many outcomes assessed including several scales and subscales.
Cicerone, 2004^11^ | Cohort | Moderate | Selection bias; intervention definition and implementation partially adequate; subjective self-report scale used for primary outcome measurement; confounding not adequately addressed; no adjustment for multiple comparisons.
Willer, 1999^12^ | Cohort | High | Potential selection bias; inadequate intervention definition; intervention implementation partially adequate; subjective self-report scale used for primary outcome measurement; minimally clinically important difference in CIQ not specified a priori; insufficient statistical analysis; confounding not adequately addressed; no adjustment for multiple comparisons.
Bell, 2005^13^ | RCT | Moderate | Well-designed study; composite outcome measures challenging to interpret; no adjustment for multiple comparisons.
Powell, 2002^14^ | RCT | Moderate | Minimally clinically important difference in BICRO-39 not specified a priori; subjective self-report scale used for primary outcome measurement; no adjustment for multiple comparisons.
Thomas, 2004^15^ | Cohort | High | Potential selection bias; subjective self-report scale used for primary outcome measurement; minimally clinically important difference not specified a priori; insufficient statistical analysis; confounding not adequately addressed; no adjustment for multiple comparisons.
Semlyen, 1998^16^ | Cohort | High | Potential selection bias; inadequate intervention definition; intervention implementation partially adequate; subjective self-report scale used for primary outcome measurement; minimally clinically important difference not specified a priori; insufficient statistical analysis; confounding not adequately addressed; no adjustment for multiple comparisons.

Appendix B. Table 2 Risk of Bias Assessment Form for RCTs

Appendix B. Table 3 Risk of Bias Assessment Form for Observational Studies