# Search Strategy

## Ovid MEDLINE Search Strategy

1. Epidemiologic studies/
2. exp case control studies/
3. exp cohort studies/
4. Case control.tw.
5. (cohort adj (study or studies)).tw.
6. Cohort analy$.tw.
7. (Follow up adj (study or studies)).tw.
8. (observational adj (study or studies)).tw.
9. Longitudinal.tw.
10. randomized controlled trial/
11. clinical trial/
12. clinical trial, phase i.pt.
13. clinical trial, phase ii.pt.
14. clinical trial, phase iii.pt.
15. clinical trial, phase iv.pt.
16. controlled clinical trial.pt.
17. randomized controlled trial.pt.
18. multicenter study.pt.
19. clinical trial.pt.
20. or/1–19
21. Craniocerebral Trauma/
22. exp Brain Injuries/
23. Cerebrovascular Trauma/
24. brain injur*.ti,ab.
25. head injur*.ti,ab.
26. tbi.ti,ab.
27. or/21–26
28. 20 and 27
29. Rehabilitation/
30. rehab*.ti,ab.
31. neurorehabilitation.ti,ab.
32. 29 or 30 or 31
33. 28 and 32
34. limit 33 to “all child (0 to 18 years)”
35. limit 34 to “all adult (19 plus years)”
36. 33 not 34
37. 35 or 36
38. limit 37 to (addresses or autobiography or bibliography or biography or case reports or clinical conference or congresses or dictionary or directory or in vitro or interactive tutorial or interview or lectures or legal cases or legislation or news or newspaper article or patient education handout or periodical index or portraits or video-audio media or webcasts)
39. 37 not 38
40. limit 39 to yr= “1980 -Current”

## PsycINFO Search Strategy

1. epidemiologic studies.mp.
2. case control.mp.
3. exp Longitudinal Studies/
4. (cohort adj (study or studies)).tw.
5. Cohort analy$.tw.
6. (Follow up adj (study or studies)).tw.
7. (observational adj (study or studies)).tw.
8. longitudinal.mp.
9. randomized controlled trial.mp.
10. clinical trial.mp. or exp Clinical Trials/
11. controlled clinical trial.mp.
12. phase i clinical trial.mp.
13. phase ii clinical trial.mp.
14. phase iii clinical trial.mp.
15. phase iv clinical trial.mp.
16. multicenter study.mp.
17. or/1–16
18. exp Traumatic Brain Injury/ or exp Head Injuries/ or craniocerebral trauma.mp.
19. brain injur*.mp.
20. exp Cerebrovascular Accidents/ or cerebrovascular trauma.mp.
21. head injur*.mp.
22. tbi.mp.
23. or/18–22
24. 17 and 23
25. exp Rehabilitation/ or exp Neuropsychological Rehabilitation/ or rehabilitation.mp.
26. rehab*.mp.
27. exp Neurorehabilitation/ or neurorehabilitation.mp.
28. or/25–27
29. 24 and 28
30. limit 29 to (100 childhood <birth to age 12 yrs> or 120 neonatal <birth to age 1 mo> or 140 infancy <age 2 to 23 mo> or 160 preschool age <age 2 to 5 yrs> or 180 school age <age 6 to 12 yrs> or 200 adolescence <age 13 to 17 yrs>)
31. limit 30 to (“300 adulthood <age 18 yrs and older>” or 320 young adulthood <age 18 to 29 yrs> or 340 thirties <age 30 to 39 yrs> or 360 middle age <age 40 to 64 yrs> or “380 aged <age 65 yrs and older>” or “390 very old <age 85 yrs and older>”)
32. 29 not 30
33. 31 or 32
34. limit 33 to yr=”1980 -Current”

## Cochrane Central Register of Controlled Trials Search Strategy

1. traumatic brain injur* and rehab*

## PEDro Search Strategy

1. traumatic brain injur* AND rehab*