# Acronyms and Abbreviations

ABI: acquired brain injury
ABIER: Evidence-based Review of Moderate to Severe Acquired Brain Injury Report
AHRQ: Association for Health Care Research and Quality
BIRCO-39: Brain Injury Community Rehabilitation Outcome-39
CENTRAL: Cochrane Central Register of Controlled Trials
CHART: Craig Handicap Assessment and Report Technique
CHART-SF: Craig Handicap Assessment and Report Technique - Short Form
CIQ: Community Reintegration Questionnaire
DRS: Disability Rating Scale
ECRI: Emergency Care Research Institute
EGOS-E: Extended Glasgow Outcome Score
EuroQoL: European Quality of Life Scale
GCS: Glasgow Coma Score
ICF: International Classification of Function, Disability and Health
ICRP: Intensive Cognitive Rehabilitation Program
ICTRP: International Controlled Trials Registry Platform
IOM: Institute of Medicine
KQ: Key Questions
MCID: minimum clinically important difference
MPAI: Mayo-Portland Assessment Inventory
NIAF: Newcastle Independence Assessment From
NIH: National Institutes of Health
NR: Not Reported
PEDro: Physiotherapy Evidence Database
PICOTS: Population, Intervention, Comparator, Outcome, Timing, Setting
PQOL: Perceived Quality of Life Scale
QCIQ: Quality of Community Integration Questionnaire
QOLI: Quality of Life Inventory
RCT: Randomized Controlled Trial
RR: Risk ratio
RTW: Return to work
SOE: Strength of Evidence
SWLS: Satisfaction with Life Scale
TBI: Traumatic Brain Injury
TEP: technical expert panel
VA: Veterans Affairs
WHO: World Health Organization