# Results

## Literature Search

Our literature search yielded 2,415 citations. From these, we provisionally accepted 106 articles for review based on abstracts and titles (Figure 2). After screening their full texts, 22 studies,50–71 published in 42 articles,50–91 were judged to have met the inclusion criteria (Appendix D). All of these studies were RCTs except one, which was a randomized crossover trial.51 The remaining 64 full-text articles were excluded (Appendix E). The primary reasons for exclusion included not studying breathing techniques, not providing primary data, not using one of the specified study designs, and being rated as poor quality. The eight publications excluded for quality concerns represented six unique studies. Most were excluded because they failed to describe multiple important areas of their methods (e.g., randomization methods and followup rates and inclusion/exclusion rules and assessment methods were all missing) and the remaining were very small trials (n=12 and 17) that either lacked comparability between groups at baseline92–94 or did not report acceptable measurement or analysis methods.95

Figure 2 Literature flow diagram

Figure 2 is a flow chart that summarizes the search and selection of articles. There were 2,375 citations identified by searching MEDLINE, PsycInfo, EMBASE, Cochrane Center Register of Controlled Trials (CCRCT), Physiotherapy Evidence Database (PEDro), Allied and Complementary Medicine Databases (AMED), Manual, Alternative and Natural Therapy Index System (MANTIS), Cumulative Index to Nursing and Allied Health Literature (CINAHL), AltHealthWatch and Indian Medical Journals (IndMED). An additional 40 citations were identified from outside sources such as reference lists. Of these, 2,309 citations were excluded after title/abstract review. The full-text of the 106 remaining citations were examined for inclusion. 64 articles were excluded for various reasons. 22 studies published in 42 articles were included in the final report.

All trials were conducted with people with symptomatic asthma. Most were limited to those with stable asthma (e.g., stable dose of asthma medication, no recent use of oral steroids, and/or no recent hospitalization for asthma). Some trials were limited to people with a certain level of beta_2_-agonist use (e.g., twice daily,50,69 twelve times per week,56 four times per week,51,58 or twice weekly52), suggesting their asthma was not well controlled. Most trials confirmed reversibility of respiratory symptoms through pulmonary function testing. Trials primarily included adults; only one trial of IMT targeted children (ages 8 to 12 years),65 and only four other trials included people younger than 16 years of age.50,53,56,58 Trials used a variety of breathing retraining techniques (Table 3), including interventions that targeted hyperventilation reduction (e.g., Buteyko breathing technique, Papworth method),50–59,71 yoga breathing techniques,60–64 IMT,65–69 and other controlled breathing approaches using prolonged exhalation or abdominal breathing.52,70,71 Four of the trials of hyperventilation reduction used alternate breathing techniques for comparison50,52,53,58 and seven used some kind of usual care, placebo, wait list, or attention control group.51,52,54–57,59 One trial had two study arms with different treatments in addition to a placebo-control group. Comparisons from this study will be discussed in multiple sections of this report.52

Table 3 Included breathing retraining Interventions and comparisons

Intervention | Description/Examples | Comparator | Number of Included Trials
Hyperventilation reduction breathing techniques | Nasal breathing, eliminating “overbreathing,” end-tidal breath-holding. Examples include the Buteyko and Papworth methods. | Control | 8^*,50–59,71^
Hyperventilation reduction breathing techniques | Nasal breathing, eliminating “overbreathing,” end-tidal breath-holding. Examples include the Buteyko and Papworth methods. | Another breathing technique | 4^*,50–59^
Yoga breathing | Diaphragmatic/abdominal breathing, slowing and regularizing breathing, prolonging expiratory phase, using manual methods or the tongue and throat muscles to impose resistance. Also known as Pranayama. | Control | 5^60–64^
Inspiratory muscle training | Use of exercises or device to increase strength of breathing muscles. | Control | 5^65–69^
Other non-hyperventilation reduction breathing techniques | Slowed breathing. | Control | 2^*,52,70,71^

* One study with three treatment arms is included in each of these groups52

Thirty-two percent of the trials described allocation as concealed. Asthma symptoms, medication use, and quality of life were usually based on self-report, and only 41 percent of the trials reported that outcomes assessments were conducted blindly. Lack of blinding may be especially problematic for pulmonary function testing, which is effort-dependent and involves coaching to get an optimal performance. Lack of blinding may also be problematic for self-reported outcomes, where social desirability could introduce bias. Most trials were small, with 68 percent including only 30 or fewer participants per treatment arm. Only a single trial included more than 100 participants per treatment arm.56 Trials were also inconsistent the degree to which they ensured the sample was limited to asthmatics: 42 percent did not report the use of pulmonary function testing to confirm an asthma diagnosis and 39 percent did not describe limiting excluding participants with other respiratory disorders or people at high risk for other respiratory disorders (e.g., smokers).

## Results of Included Studies

We discuss results for the five different types of comparisons separately: hyperventilation reduction breathing techniques compared with control groups (Table 4) or with other nonhyperventilation reduction breathing techniques (Table 5); yoga breathing compared with control groups (Table 6); IMT compared with control groups (Table 7); and other nonhyperventilation reduction breathing techniques compared with control groups (Table 8). Table 9 briefly describes the instruments, including directionality, to aid in the interpretation of standardized scales (see end of chapter for all tables).

Table 4 Overview of results: hyperventilation reduction breathing techniques versus control

Study | Followup^*^ | Group | N Randomized | Description | Intensity (Total Hours) | Baseline SABA Use | Baseline ICS Use (mcg/d) | Baseline FEV_1_ (L) | Asthma sx | Reliever Med Use | Controller Med Use | QoL | FEV_1_ | PEF | Quality^¶^ | Applicability to U.S. Health Care Setting
Grammatopoulou 2011^54^ | 26w | IG | 20 | Diaphragm, nasal breathing; short pause | 13 | NR | NR | 83.7 | ↓ | | | | ↔ | | ++ | Conducted in Greece, limited to those with mild or moderate asthma
Grammatopoulou 2011^54^ | 26w | CG | 20 | Usual care | NR | NR | NR | 83.7 | ↓ | | | | ↔ | | ++ | Conducted in Greece, limited to those with mild or moderate asthma
Cooper 2003^52^ | 26w | IG1 | 30 | BBT^†^ | 10 | 2 puffs/d^‡^ | 657 | 80 | ↓ ↔ | ↓ | ↔ | ↔ | ↔ | | ++ | Conducted in the UK, used certified BBT practitioner
Cooper 2003^52^ | 26w | CG | 29 | Sham device | NR, 1 session | 2 puffs/d^‡^ | 657 | 80 | ↓ ↔ | ↓ | ↔ | ↔ | ↔ | | ++ | Conducted in the UK, used certified BBT practitioner
McGowan56,99 | 26w | IG | 200 | BBT | 2h + 7 sessions | 18 puffs/w | NR | 76.7 | ↓↓ (vs each group) | ↓↓ (vs each group) | ↓↓ (vs each group) | | ↑ ↔ | | ++ | Conducted in Scotland, used certified BBT practitioner
McGowan56,99 | 26w | CG1 | 200 | Nurse education | 2h + 7 sessions | 18 puffs/w | NR | 76.7 | ↓↓ (vs each group) | ↓↓ (vs each group) | ↓↓ (vs each group) | | ↑ ↔ | | ++ | Conducted in Scotland, used certified BBT practitioner
McGowan56,99 | 26w | CG2 | 200 | Brief asthma education | 2h | 18 puffs/w | NR | 76.7 | ↓↓ (vs each group) | ↓↓ (vs each group) | ↓↓ (vs each group) | | ↑ ↔ | | ++ | Conducted in Scotland, used certified BBT practitioner
Holloway 2007^55,72^ | 52w | IG | 39 | Papworth^§^ | 5 | NR | NR | 89.6 | ↓↓ | | | | ↔ | ↔ | ++ | Conducted in the UK, used respiratory therapist
Holloway 2007^55,72^ | 52w | CG | 46 | Usual care | NR | NR | NR | 89.6 | ↓↓ | | | | ↔ | ↔ | ++ | Conducted in the UK, used respiratory therapist
Opat 2000^57,77^ | 4w | IG | 18 | BBT video | 19.8 | 404 mcg/d | 430 | NR | ↔ | ↓ | ↔ | ↑ | | ↔ | ++ | Conducted in Australia, all-volunteer sample
Opat 2000^57,77^ | 4w | CG | 18 | Landscape video | 18.6 | 404 mcg/d | 430 | NR | ↔ | ↓ | ↔ | ↑ | | ↔ | ++ | Conducted in Australia, all-volunteer sample
Thomas 2009^59,79–81^ | 26w | IG | 94 | HRBT | 2–2.5 | 1.4 dose/d | 400^‡^ | 89.5 | ↔ | ↔^**^ | ↔^**^ | ↑ | ↔^**^ | | ++ | Conducted in the UK
Thomas 2009^59,79–81^ | 26w | CG | 89 | Asthma education | 2–2.5 | 1.4 dose/d | 400^‡^ | 89.5 | ↔ | ↔^**^ | ↔^**^ | ↑ | ↔^**^ | | ++ | Conducted in the UK
Thomas 2003^71,78,82^ | 26w | IG | 17 | HRBT | 1.25 | 1.5 can/3m | 600 | NR | ↓ ↔ †† | ↔ | ↔ | ↑ ↔ †† | | | ++ | Conducted in the UK, limited to those with Nijmegen scores suggestive of dysfunctional breathing
Thomas 2003^71,78,82^ | 26w | CG | 16 | Asthma education session | 1 | 1.5 can/3m | 600 | NR | ↓ ↔ †† | ↔ | ↔ | ↑ ↔ †† | | | ++ | Conducted in the UK, limited to those with Nijmegen scores suggestive of dysfunctional breathing
Cooper 2009║51,75,89 | 4w | IG | 51 | Mouth-taping | NA | 10 puffs/w^‡^ | 567 | 86.2 | ↔ | ↔ | | ↔ | | ↔ | ++ | Conducted in the UK
Cooper 2009║51,75,89 | 4w | CG | 51 | Usual care | NA | 10 puffs/w^‡^ | 567 | 86.2 | ↔ | ↔ | | ↔ | | ↔ | ++ | Conducted in the UK

BBT: Buteyko breathing technique; can: canister(s); CG: control group; d: day(s); FEV_1_: forced expiratory volume in 1 second; h: hour(s); ICS: inhaled corticosteroids; IG: intervention group; mcg: microgram(s); med: medication; NA: not applicable; NR: not reported; PEF: peak expiratory flow; QoL: quality of life; SABA: short-acting beta_2_-agonists; sx: symptoms; UK: United Kingdom; w: week(s)

* Time to longest followup

† Also included dietary restrictions, stress management and instruction to avoid oversleeping

‡ Median

§ Also includes stress management

║ Crossover study design, mouth-taping and control phases

¶ All trials were rated “Fair”; further gradation is provided as follows: +++ = Minor quality issues, but not meeting criteria for “Good” quality; ++ = Between +++ and + trials in quality; + = Substantial quality issues, but no clear fatal flaw

** Outcome was assessed at 4 weeks only

†† Statistically significant only at 4w followup

↑: Intervention group shows greater improvement than control group, small to moderate effect

↑↑: Intervention group shows greater improvement than control group, large effect (standardized ES >0.8, absolute change from baseline of 50% or more in intervention group and 10% or less in the control group, or comparable)

↔: Trial shows no consistent differences between groups

↑↔: Mixed results

Table 5 Overview of results: hyperventilation reduction breathing techniques versus nonhyperventilation reduction breathing techniques

Study | Followup^*^ | Group | N Randomized | Description | Intensity (Total Hours) | Baseline SABA Use | Baseline ICS Use (mcg/d) | Baseline FEV_1_ (L) | Asthma Sx or Control | Reliever Med Use | Controller Med Use | QoL | FEV_1_ | PEF | Quality║ | Applicability to U.S. Health Care Setting
Cooper 2003^52^ | 26w | IG1 | 30 | BBT^†^ | 10 | 2 puffs/d^‡^ | 657 | 80 | ↔ | ↓BBT | ↔ | ↔ | ↔ | | ++ | Conducted in the UK, used certified BBT practitioner, used device that may not be widely available
Cooper 2003^52^ | 26w | IG2 | 30 | Yoga breathing device | NR, 1 session, practice 6m | 2 puffs/d^‡^ | 657 | 80 | ↔ | ↓BBT | ↔ | ↔ | ↔ | | ++ | Conducted in the UK, used certified BBT practitioner, used device that may not be widely available
Bowler 1998^50,73,88^ | 13w | IG1 | 19 | BBT sessions | 7–10.5 or more | 892 mcg/d | 1250 | 74 | ↔ | ↓BBT | ↔ | ↔ | ↔ | ↔ | + | Conducted in Australia, all volunteer sample, used certified BBT practitioner, high levels of baseline asthma medication use
Bowler 1998^50,73,88^ | 13w | IG2 | 20 | Abdominal breathing, asthma education | 7–10.5 | 892 mcg/d | 1250 | 74 | ↔ | ↓BBT | ↔ | ↔ | ↔ | ↔ | + | Conducted in Australia, all volunteer sample, used certified BBT practitioner, high levels of baseline asthma medication use
Cowie 2008^53^ | 26w | IG1 | 65 | BBT sessions | NR, 5 sessions | NR | 840 | 81 | ↔ | | ↓BBT | ↔^§^ | ↔ | | ++ | Conducted in Canada, university setting, used certified BBT practitioner, used certified physical therapist
Cowie 2008^53^ | 26w | IG2 | 64 | Physical therapy sessions | NR, 5 sessions | NR | 840 | 81 | ↔ | | ↓BBT | ↔^§^ | ↔ | | ++ | Conducted in Canada, university setting, used certified BBT practitioner, used certified physical therapist
Slader 2006^58^ | 28w | IG1 | 28 | BBT video | 90 | 3 puffs/d | NR | 80 | ↔^§^ | ↔^§^ | ↔^§^ | ↔ | ↔ | | +++ | Conducted in Australia, limited to those with moderate to severe asthma, low baseline scores on mood domains on QoL questionnaire, conducted in research setting
Slader 2006^58^ | 28w | IG2 | 29 | Video-based controlled breathing, mobility and stretching | 90 | 3 puffs/d | NR | 80 | ↔^§^ | ↔^§^ | ↔^§^ | ↔ | ↔ | | +++ | Conducted in Australia, limited to those with moderate to severe asthma, low baseline scores on mood domains on QoL questionnaire, conducted in research setting

BBT: Buteyko breathing technique; CG: control group; d: day(s); FEV_1_: forced expiratory volume in 1 second; h: hour(s); ICS: inhaled corticosteroids; IG: intervention group; mcg: microgram(s); med: medication; NA: not applicable; NR: not reported; PEF: peak expiratory flow; QoL: quality of life; SABA: short-acting beta_2_-agonists; sx: symptoms; UK: United Kingdom; w: week(s)

* Time to longest followup

† Also included dietary restrictions, stress management and instruction to avoid oversleeping

‡ Median puffs per day, typical dose per puff = 100 mcg

§ No difference between groups but both groups showed improvement

║ All trials were rated “Fair”; further gradation is provided as follows: +++ = Minor quality issues, but not meeting criteria for “Good” quality; ++ = Between +++ and + trials in quality; + = Substantial quality issues, but no clear fatal flaw

↑: Intervention group shows greater improvement than control group, small to moderate effect

↑↑: Intervention group shows greater improvement than control group, large effect (standardized ES >0.8, absolute change from baseline of 50% or more in intervention group and 10% or less in the control group, or comparable)

↔: Trial shows no consistent differences between groups

↑↔: Mixed results

Table 6 Overview of results: yoga breathing techniques versus control

Study | Followup^*^ | Group | N Randomized | Description | Intensity (Total Hours) | Baseline SABA Use | Baseline ICS Use (mcg/d) | Baseline FEV_1_ (L) | Asthma Sx | Reliever Med Use | Controller Med Use | QoL | FEV_1_ | PEF | Quality║ | Applicability to U.S. Health Care Setting
Khare 1991^60^ | 26w | IG | 17 | Daily yoga | 210 | NR | NR^†^ | NR | ↓ | | ↓^‡^ | | ↑ | ↑↑ | + | Conducted in India, limited to male vegetarians age 25 to 50, standard of care did not include ICS
Khare 1991^60^ | 26w | CG | 17 | Usual care | NR | NR | NR^†^ | NR | ↓ | | ↓^‡^ | | ↑ | ↑↑ | + | Conducted in India, limited to male vegetarians age 25 to 50, standard of care did not include ICS
Vempati 2009^64,74,83–87^ | 8w | IG | 30 | Yoga practice and lectures^§^ | 56 | 2.1 puffs/d^¶^ | 339^**^ | 66 | ↓ | ↓↓ | | ↑↑ | ↑↑ | ↑ | ++ | Conducted in India, mild to moderate asthma only
Vempati 2009^64,74,83–87^ | 8w | CG | 30 | Usual care | NR, 1 session | 2.1 puffs/d^¶^ | 339^**^ | 66 | ↓ | ↓↓ | | ↑↑ | ↑↑ | ↑ | ++ | Conducted in India, mild to moderate asthma only
Kligler 2011^61^ | 26w | IG | 77 | Yoga breathing^††^ | 6–9 | NR | NR | NR | ↓ | | | ↑ | ↔ | | + | Self-identified sample, intervention included dietary change, supplements and journaling
Kligler 2011^61^ | 26w | CG | 77 | Usual care | NR | NR | NR | NR | ↓ | | | ↑ | ↔ | | + | Self-identified sample, intervention included dietary change, supplements and journaling
Saxena 2009^63^ | 12w | IG | 25 | Yoga breathing exercise | 56 | NR | NR | 72 | ↓↓ | | | | ↑↑ | ↑↑ | + | Conducted in India, limited to those with 26w experience with yoga and no regular use of medication (or advised to discontinue medication if using)
Saxena 2009^63^ | 12w | CG | 25 | Meditation | 56 | NR | NR | 72 | ↓↓ | | | | ↑↑ | ↑↑ | + | Conducted in India, limited to those with 26w experience with yoga and no regular use of medication (or advised to discontinue medication if using)
Sabina 2005^62^ | 16w | IG | 29 | Yoga class | 12 | 1 puffs/d | NR | NR | ↔ | ↔ | | ↔ | ↔ | ↔ | ++ | Mild to moderate asthma only, all self-identified sample, conducted in research setting
Sabina 2005^62^ | 16w | CG | 33 | Stretching class | 12 | 1 puffs/d | NR | NR | ↔ | ↔ | | ↔ | ↔ | ↔ | ++ | Mild to moderate asthma only, all self-identified sample, conducted in research setting

CG: control group; d: day(s); FEV_1_: forced expiratory volume in 1 second; h: hour(s); ICS: inhaled corticosteroids; IG: intervention group; mcg: microgram(s); med: medication; NA: not applicable; NR: not reported; PEF: peak expiratory flow; QoL: quality of life; SABA: short-acting beta_2_-agonists; sx: symptoms; w: week(s)

* Time to longest followup

† 19/34 (56%) “disturbed sleep and dyspnea on daily routine work which was relieved by oral drugs”; 8/34 (24%) “asthma required injection frequently to control dyspnea or admission to hospital”

‡ Reduction in dose to “control dyspnea,” type of medication not specified

§ Also includes dietary advice, instruction on cleansing techniques, meditation and relaxation

║ All trials were rated “Fair”; further gradation is provided as follows: +++ = Minor quality issues, but not meeting criteria for “Good” quality; ++ = Between +++ and + trials in quality; + = Substantial quality issues, but no clear fatal flaw

¶ Includes 11 with missing data, unclear if nonusers or simply missing

** Includes 25 with missing data, unclear if nonusers or simply missing

†† Also include dietary advice

↑: Intervention group shows greater improvement than control group, small to moderate effect

↑↑: Intervention group shows greater improvement than control group, large effect (standardized ES >0.8, absolute change from baseline of 50% or more in intervention group and 10% or less in the control group, or comparable)

↔: Trial shows no consistent differences between groups

↑↔: Mixed results

Table 7 Overview of results: inspiratory muscle training versus control

Study | Followup^*^ | Group | N Randomized | Description | Intensity (Total Hours) | Baseline SABA Use | Baseline ICS Use (mcg/d) | Baseline FEV_1_ (L) | Asthma sx | Reliever Med Use | Controller Med Use | QoL | FEV_1_ | PEF | Quality^†^ | Applicability to U.S. Health Care Setting
Lima 2008^65^ | 13w | IG | 25 | IMT, meds and asthma education | 14.6 | NR | NR | NR | ↓↓ | ↓↓ | | | | ↑↑ | + | Conducted in Brazil, limited to 8- to 12-year-old children with untreated, uncontrolled asthma
Lima 2008^65^ | 13w | CG | 25 | Meds, asthma education | 3 | NR | NR | NR | ↓↓ | ↓↓ | | | | ↑↑ | + | Conducted in Brazil, limited to 8- to 12-year-old children with untreated, uncontrolled asthma
Shaw 2011^66,91^ | 8w | IG | 22 | Abdominal strengthening | NR | NR | NR | NR | | | | | ↑↑ | | + | Conducted in South Africa, only moderate-persistent asthma
Shaw 2011^66,91^ | 8w | CG | 22 | Usual care | NR | NR | NR | NR | | | | | ↑↑ | | + | Conducted in South Africa, only moderate-persistent asthma
Weiner 1992^67^ | 26w | IG | 15 | IMT | 60 | 6 puffs/d | NR | 59 | ↓ | ↓↓ | | | ↑↑ | | ++ | Conducted in Israel, moderate to severe asthma only
Weiner 1992^67^ | 26w | CG | 15 | Sham device | 60 | 6 puffs/d | NR | 59 | ↓ | ↓↓ | | | ↑↑ | | ++ | Conducted in Israel, moderate to severe asthma only
Weiner 2002^68^ | 20w | IG | 11 | IMT | 60 | 3.2 puffs/d | NR | 83 | | ↔ ↓ | | | ↔ | | + | Conducted in Israel, limited to females with mild to moderate asthma
Weiner 2002^68^ | 20w | CG | 11 | Sham device | 60 | 3.2 puffs/d | NR | 83 | | ↔ ↓ | | | ↔ | | + | Conducted in Israel, limited to females with mild to moderate asthma
Weiner 2000^69^ | 13w | IG | 12 | IMT | 36 | 2.7 puffs/d | NR | 91 | | ↔ ↓ | | | | | + | Conducted in Israel
Weiner 2000^69^ | 13w | CG | 11 | Sham device | 36 | 2.7 puffs/d | NR | 91 | | ↔ ↓ | | | | | + | Conducted in Israel

CG: control group; d: day(s); FEV_1_: forced expiratory volume in 1 second; h: hour(s); ICS: inhaled corticosteroids; IG: intervention group; IMT: inspiratory muscle training; mcg: microgram(s); med: medication; NA: not applicable; NR: not reported; PEF: peak expiratory flow; QoL: quality of life; SABA: short-acting beta_2_-agonists; sx: symptoms; w: week(s)

* Time to longest followup

† All trials were rated “Fair”; further gradation is provided as follows: +++ = Minor quality issues, but not meeting criteria for “Good” quality; ++ = Between +++ and + trials in quality; + = Substantial quality issues, but no clear fatal flaw

↑: Intervention group shows greater improvement than control group, small to moderate effect

↑↑: Intervention group shows greater improvement than control group, large effect (standardized ES >0.8, absolute change from baseline of 50% or more in intervention group and 10% or less in the control group, or comparable)

↔: Trial shows no consistent differences between groups

↑↔: Mixed results

Table 8 Overview of results: nonhyperventilation reduction breathing techniques versus control

Study | Followup^*^ | Group | N randomized | Description | Intensity (Total Hours) | Baseline SABA Use | Baseline ICS Use (mcg/d) | Baseline FEV_1_ (L) | Asthma sx | Reliever Med Use | Controller Med Use | QoL | FEV_1_ | PEF | Quality^¶^ | Applicability to U.S. Health Care Setting
Lehrer 2004^70,76,90^ | 12w | IG | 23 | Prolonged exhalation with HRV biofeedback | NR, 10 sessions | NR | NR | NR | ↔ § | | ↔ § | | ↔║ | | ++ | All volunteer sample, strict adherence to NAEPP guidelines with monthly visits, conducted in research setting
Lehrer 2004^70,76,90^ | 12w | CG1 | 22 | HRV biofeedback | NR, 10 sessions | NR | NR | NR | ↔ § | | ↔ § | | ↔║ | | ++ | All volunteer sample, strict adherence to NAEPP guidelines with monthly visits, conducted in research setting
Lehrer 2004^70,76,90^ | 12w | CG2 | 24 | Sham device^†^ | NR, 10 sessions | NR | NR | NR | ↔ § | | ↔ § | | ↔║ | | ++ | All volunteer sample, strict adherence to NAEPP guidelines with monthly visits, conducted in research setting
Lehrer 2004^70,76,90^ | 12w | CG3 | 25 | Waitlist | Waited for 30w | NR | NR | NR | ↔ § | | ↔ § | | ↔║ | | ++ | All volunteer sample, strict adherence to NAEPP guidelines with monthly visits, conducted in research setting
Cooper 2003^52^ | 26w | IG2 | 30 | Prolonged exhalation device | NR, 1 session, 6m practice | 2 puffs/d^‡^ | 657 | 80 | ↔ | ↔ | ↔ | ↔ | ↔ | | ++ | Conducted in the UK, used device that may not be widely available
Cooper 2003^52^ | 26w | CG | 29 | Sham device | NR, 1 session | 2 puffs/d^‡^ | 657 | 80 | ↔ | ↔ | ↔ | ↔ | ↔ | | ++ | Conducted in the UK, used device that may not be widely available

CG: control group; d: day(s); FEV_1_: forced expiratory volume in 1 second; h: hour(s); HRV: heart rate variability; ICS: inhaled corticosteroids; IG: intervention group; mcg: microgram(s); med: medication; NA: not applicable; NAEPP: National Asthma Education and Prevention Program; NR: not reported; PEF: peak expiratory flow; QoL: quality of life; SABA: short-acting beta_2_-agonists; sx: symptoms; UK: United Kingdom; w: week(s)

* Time to longest followup

† Includes practice (but with no instruction) of maintaining a state of relaxed alertness, classical music tapes

‡ Median

§ No differences between biofeedback groups with and without breathing retraining component; both of these groups did differ from either the sham device and waitlist groups

║ No differences in “spirometry”, specific measures NR

¶ All trials were rated “Fair”; further gradation is provided as follows: +++ = Minor quality issues, but not meeting criteria for “Good” quality; ++ = Between +++ and + trials in quality; + = Substantial quality issues, but no clear fatal flaw

↑: Intervention group shows greater improvement than control group, small to moderate effect

↑↑: Intervention group shows greater improvement than control group, large effect (standardized ES >0.8, absolute change from baseline of 50% or more in intervention group and 10% or less in the control group, or comparable)

↔: Trial shows no consistent differences between groups

↑↔: Mixed results

Table 9 Instruments used for measuring asthma symptoms, control, quality of life, or related outcomes

Outcome Measure | Instrument | Number of Items | Range | Directionality (Higher score = better or worse) | Constructs Measured, Subscales | Number of Included Studies Using Instrument
Symptom, Severity, or Control | Asthma Control Questionnaire (ACQ)100 | 7 | 0–6 | Worse | Symptoms, beta_2_-agonist use, pulmonary function (FEV_1_) | 3
Symptom, Severity, or Control | Asthma Control Diary (ACD)101 | 8 | 0–6 | Worse | Morning score: PEFR, awakenings, symptom severity; Bedtime score: activity limitations, shortness of breath, wheezing, bronchodilator use, PEF | 1
Symptom, Severity, or Control | Physician/Patient Global Assessment for Asthma Control | NR | 0–100 | Better | Not described | 1
Symptom, Severity, or Control | Asthma Control Test (ACT)96 | 22 | 1–5 | Worse | Symptoms and control, activity, health care use | 1
Asthma-Related Quality of Life | St. George’s Respiratory Questionnaire (SGRQ)102 | 76 | 0–100 | Worse | Symptoms, activity, impacts | 1
Asthma-Related Quality of Life | Asthma Quality of Life Questionnaire (AQLQ-Marks)103 | 20 | 0–4 | Worse | Breathlessness and physical restriction, mood disturbance, social disruption, concern for health | 5
Asthma-Related Quality of Life | Mini-Juniper Quality of Life Questionnaire (Mini-Juniper)46 | 15 | 1–7 | Better | Overall quality of life, symptom severity, environment impact on asthma, emotional impact of asthma, activity limitations | 5
Asthma-Related Quality of Life | Asthma Quality of Life Questionnaire (AQLQ-Juniper)47 | 32 | 1–7 | Better | Symptoms, emotions, environment, physical activities, practical problems | 3
Dysfunctional Breathing | Nijmegen Questionnaire104 | 16 | 1–5 | Worse | Hyperventilation syndrome (chest pain, feeling tense, blurred vision, dizzy spells, feeling confused, faster or deeper breathing, short of breath, tight feelings in chest, bloated feeling in stomach, tingling fingers, unable to breathe deeply, stiff fingers or arms, tight feelings round mouth, cold hands or feet, palpitations, feeling of anxiety) | 5
General Functioning and Quality of Life | Short-form (SF-36) Health Survey105 | 36 | 0–100 | Better | Vitality, physical functioning, bodily pain, general health perceptions, physical role functioning, emotional role functioning, social role functioning, mental health | 3^*^
Mental Health | Hospital Anxiety and Depression Scale (HADS)106 | 14 | 0–3 | Worse | Anxiety, depression | 2

FEV_1_: forced expiratory volume in 1 second; PEF: peak expiratory flow: PEFR: peak expiratory flow rate

* Includes one study that used the SF-12

## Key Question 1 In adults and children 5 years of age and older with asthma, does the use of breathing exercises and/or retraining techniques improve health outcomes, including: symptoms (e.g., cough, wheezing, dyspnea); health-related quality of life (general and/or asthma-specific); acute asthma exacerbations; reduced use of quick-relief medications or reduced use of long-term control medications, when compared with usual care and/or other breathing techniques alone or in combination with other intervention strategies?

### Hyperventilation Reduction Breathing Techniques Versus Control Group

Key Points:

- We found moderate evidence that hyperventilation reduction breathing technique interventions with 5 or more hours of direct instruction may reduce asthma symptoms and the use of reliever medication in adults, though evidence was limited to a fairly small number of trials, most of which were at moderate risk of bias due to factors such as small sample sizes, high or differential attrition, and lack of appropriate blinding.
- Evidence is low or insufficient that hyperventilation reduction training affects controlled medication use, quality of life, or functioning in adults and children.

Eight trials (n=1,088) compared breathing retraining targeting hyperventilation reduction with a control group. Seven were RCTs52,54–57,59,71 and one was a randomized crossover trial51 (Table 4; Appendix D, Evidence Table 1a). The 4-week cross-over trial focused only on one component of the Buteyko breathing technique, specifically mouth-taping,51 while the remaining provided broader instruction in modification of breathing (Appendix D, Evidence Table 1b). Interventions generally involved controlled, shallow breathing, and encouraging diaphragmatic breathing over chest breathing, with a breath-hold at the end of the exhalation. They advocated breathing through the nose at all times, and in some trials participants were encouraged to use a porous tape to hold the mouth closed at night while sleeping. They trained users to limit what they term “overbreathing” with sighs, yawns, and gasps. They encouraged clients to use breathing techniques when they experienced asthma symptoms for 5 to 10 minutes before using bronchodilators.

Four of these trials involved fairly extensive interventions, reporting 6 to 12 months of followup.52,54–56 These trials provided 5 to 13 hours of contact with instructors, encouraged daily practice at home, and two of these included additional lifestyle components beyond breathing retraining, of dietary and sleep advice52 and stress management.52,55 Only one of these four trials included a control group with matching treatment intensity,56 the others compared hyperventilation reduction breathing training to usual care,54,55 or a sham breathing training device.52 One trial was limited to people with dysfunctional breathing, according to the Nijmegen questionnaire.71 This instrument was designed to identify patients with chronic or habitual breathing patterns that induce hyperventilation, and assesses symptoms purported to identify hyperventilation (some of which may also be related to asthma symptoms) such as accelerated or deepened breathing, being unable to breathe deeply, palpitations, tightness around the mouth, tingling fingers, and dizzy spells.

Three lower-intensity interventions targeted breathing retraining only (i.e., included no co-interventions that were not directly targeting breathing retraining), but did attempt to provide comprehensive training rather than focusing only on a single aspect of the training. One trial used a video for both instruction and daily practice,57 and the two others, conducted by the same researcher using very similar interventions, offered 1 to 2 hours of direct instruction.59,71 Interventionists in all of these trials encouraged daily practice at home. One trial reported only 4-week outcomes,57 and the other had 26-week followup for some or all outcomes.59,71 Both trials attempted to provide attention-control comparators, one with relaxing landscape videos57 and the other with general asthma education.59

Among all of the hyperventilation reduction trials with control group comparators, three used the Buteyko method,52,56,57 three used the Papworth method or were described as similar to the Papworth method,55,59,71 and one did not identify its methods as being either Buteyko or Papworth, but the description of the intervention was consistent with Buteyko and Papworth breathing methods,54 and one addressed only a single, narrow aspect of the Buteyko method (mouth taping).51

All trials were rated as fair quality (Table 10). Two of the trials suffered from fairly high attrition52,59 and three had greater attrition in the intervention group by at least ten percentage points at one or more followups.52,55,59,71 Allocation concealment was reported in only three trials,54,56,59 and outcomes assessment was clearly blinded in only four of the trials.51,52,54,56 Only two of the RCTs randomized more than 50 participants per group,56,59 and three trials had only 1-month of followup for some or all outcomes.51,57,59

Table 10 Quality and applicability issues: hyperventilation reduction breathing techniques versus control

Study | Study Design | Followup | Group | N Randomized | Retention | Allocation Concealment | Blinding of Outcomes Assessment | PFT for Asthma Confirmation | Excluded Those With Other Resp. d/o | Handling of Missing Data | Overall Quality Rating^†^ | Other Quality Concerns or Clarifications | Factors Limiting Applicability to U.S. Health Care Settings
Cooper 2003^52^ | RCT | 26w | IG1 (BBT) | 30 | 77% | NR | Yes | Yes | Likely^*^ | LOCF | ++ | Unclear which baseline differences were controlled for, many comparisons on small number of participants | Conducted in the UK, used certified BBT practitioner
Cooper 2003^52^ | RCT | 26w | CG | 30 | 80% | NR | Yes | Yes | Likely^*^ | LOCF | ++ | Unclear which baseline differences were controlled for, many comparisons on small number of participants | Conducted in the UK, used certified BBT practitioner
Grammatopoulou 2011^54^ | RCT | 26w | IG (HRBT) | 20 | 100% | Yes | Yes | NR | NR | NA | ++ | Assessment of asthma dx not described; Exclusion for other respiratory d/o NR, but did exclude smokers and those age ≥60 | Conducted in Greece, only 14% of those sent invitation were randomized (recruited from attendees of asthma department)
Grammatopoulou 2011^54^ | RCT | 26w | CG | 20 | 100% | Yes | Yes | NR | NR | NA | ++ | Assessment of asthma dx not described; Exclusion for other respiratory d/o NR, but did exclude smokers and those age ≥60 | Conducted in Greece, only 14% of those sent invitation were randomized (recruited from attendees of asthma department)
Holloway 2007^55,72^ | RCT | 26w | IG (Papworth) | 39 | 85% | NR | No | U | Likely^*^ | None | ++ | More smokers in IG but smoking not controlled for in analysis; PFT for confirmation unclear, recruited from registry | Conducted in the UK, used respiratory therapist
Holloway 2007^55,72^ | RCT | 26w | CG | 46 | 98% | NR | No | U | Likely^*^ | None | ++ | More smokers in IG but smoking not controlled for in analysis; PFT for confirmation unclear, recruited from registry | Conducted in the UK, used respiratory therapist
Holloway 2007^55,72^ | RCT | 52w | IG | 39 | 82% | NR | No | U | Likely^*^ | None | ++ | More smokers in IG but smoking not controlled for in analysis; PFT for confirmation unclear, recruited from registry | Conducted in the UK, used respiratory therapist
Holloway 2007^55,72^ | RCT | 52w | CG | 46 | 87% | NR | No | U | Likely^*^ | None | ++ | More smokers in IG but smoking not controlled for in analysis; PFT for confirmation unclear, recruited from registry | Conducted in the UK, used respiratory therapist
McGowan 2003^56,99^ | RCT | 26w | IG (BBT) | 200 | 90% | Yes | Yes | Yes | Yes | None | ++ | Specific use of spirometry to determine asthma dx not described; no description of refusals or exclusions prior to randomization | Conducted in UK, used Registered BBT practitioner
McGowan 2003^56,99^ | RCT | 26w | CG1 (Nurse Ed) | 200 | 82.5% | Yes | Yes | Yes | Yes | None | ++ | Specific use of spirometry to determine asthma dx not described; no description of refusals or exclusions prior to randomization | Conducted in UK, used Registered BBT practitioner
McGowan 2003^56,99^ | RCT | 26w | CG2 (Intro ed) | 200 | 73.0% | Yes | Yes | Yes | Yes | None | ++ | Specific use of spirometry to determine asthma dx not described; no description of refusals or exclusions prior to randomization | Conducted in UK, used Registered BBT practitioner
Opat 2000^57,77^ | RCT | 4w | IG (BBT) | 18 | 89% | U | NR | No | NR, but age limited to ≤50 | None | ++ | Allocation concealed from participant, NR if concealed from research staff | Conducted in Australia, all-volunteer sample
Opat 2000^57,77^ | RCT | 4w | CG | 18 | 89% | U | NR | No | NR, but age limited to ≤50 | None | ++ | Allocation concealed from participant, NR if concealed from research staff | Conducted in Australia, all-volunteer sample
Thomas 2009^59,79–81^ | RCT | 4w | IG (HRBT) | 94 | 78% | Yes | U | NR | Yes | LOCF | ++ | Blinding of nonself-report outcomes NR | Conducted in the UK
Thomas 2009^59,79–81^ | RCT | 4w | CG | 89 | 89% | Yes | U | NR | Yes | LOCF | ++ | Blinding of nonself-report outcomes NR | Conducted in the UK
Thomas 2009^59,79–81^ | RCT | 26w | IG | 94 | 67%^‡^ | Yes | U | NR | Yes | LOCF | ++ | Blinding of nonself-report outcomes NR | Conducted in the UK
Thomas 2009^59,79–81^ | RCT | 26w | CG | 89 | 74%^‡^ | Yes | U | NR | Yes | LOCF | ++ | Blinding of nonself-report outcomes NR | Conducted in the UK
Thomas 2003^71,78,82^ | RCT | 26w | IG (HRBT) | 17 | 94% | NR | NR | Yes | NR | None | ++ | | Conducted in the UK, limited to those with Nijemegen scores suggestive of dysfunctional breathing
Thomas 2003^71,78,82^ | RCT | 26w | CG | 16 | 75% | NR | NR | Yes | NR | None | ++ | | Conducted in the UK, limited to those with Nijemegen scores suggestive of dysfunctional breathing
Cooper 2009^51,75,89^ | Cross-over RCT | 4w | IG (mouth-taping) | 51║ | 98% | NR | Yes | Yes | Likely^*^ | None | ++ | Handling of other respiratory illness NR, but did exclude those with | Conducted in the UK
Cooper 2009^51,75,89^ | Cross-over RCT | 4w | CG | 51║ | 98% | NR | Yes | Yes | Likely^*^ | None | ++ | Handling of other respiratory illness NR, but did exclude those with | Conducted in the UK

BBT: Buteyko breathing technique; CG: control group; d/o: disorder(s); HRBT: hyperventilation reduction breathing technique; IG: intervention group; LOCF: last observation carried forward; NR: not reported; PFT: pulmonary function test; RCT: randomized controlled trial; resp: respiratory; U: unclear; UK: United Kingdom; US: United States; w: week(s)

* Did not specifically report excluding those with other respiratory disorders, but did report excluding those with other disorders without listed the specific disorders excluded.

† All trials were rated “Fair”; further gradation is provided as follows: +++ = Minor quality issues, but not meeting criteria for “Good” quality; ++ = Between +++ and + trials in quality; + = Substantial quality issues, but no clear fatal flaw

‡ Followup at 26w only measured for quality of life

║ Crossover study design, mouth-taping and control phases

Six of these trials were conducted in the United Kingdom,51,52,55,56,59,71 one in was conducted in Greece,54 and one was conducted in Australia.57 All trials were conducted in health care settings. The minimum ages of included participants ranged from 14 to 18 years, and most trials included adults up to ages 60 to 72 years. The average baseline reliever used in most trials was one to two puffs per day, generally along with 400 to 600 mcg of ICS use daily (in beclomethasone equivalent), and FEV_1_ between 80 percent and 89 percent. The Australian trial had somewhat higher reliever medication use than the other four, with an average of 404 mcg per day at baseline (along with an average 430 mcg of ICS daily).57

#### Asthma Symptoms

All eight trials reported some type of asthma symptom outcome, which was usually a standardized questionnaire (Table 4; Appendix D, Evidence Table 1c). All four of the most-intensive and comprehensive interventions reported improvements in asthma symptoms at 6- to 12- months of followup.52,54–56 Only four of the trials provided sufficient information to pool in a meta-analysis of asthma symptom scores, three of the four most intensive trials,54–56 and one lower-intensity trial comparing 2 to 2.5 hours of Buteyko training with 2 to 2.5 hours of asthma education.59 The standardized pooled effect size (or standardized mean difference [SMD]) for the four trials with sufficient data to be included in a meta-analysis was −1.39 (95% confidence interval [CI], −2.61 to −0.17, Figure 3).54–56,59 This analysis had very high statistical heterogeneity (I^2^=97.1) and a wide range of effect sizes. However, because the pooled effect is very similar to effect seen in two of the trials, and the other two are approximately equidistant from the pooled estimate in opposite directions, the pooled effect may be a reasonable estimate for an average effect despite the high heterogeneity.

Figure 3 Effect of hyperventilation reduction techniques on asthma symptoms at 6 to 12 months

CI: confidence interval; CG: control group; est: estimated; IG: intervention group; N: sample size; SD: standard deviation; SMD: standardized mean difference

Figure 3 displays a forest plot of the standardized pooled effect size or standardized mean difference (SMD) of four hyperventialtion reduction trials (versus control) on asthma symptoms. The SMD was −1.39 (95% CI, −2.61 to −0.17), meaning that intervention participants showed greater reductions in asthma symptoms than control group participants. However, statistical heterogeneity was very high (I2=97.1).

The largest trial showed the largest effect, with SMD of −2.58 (95% CI, −2.86 to −2.29). Symptom ratings on a scale of 0 (no symptoms) to 3 (severe symptoms) dropped from an average of 2.2 at baseline for all groups to 0.7 in the Buteyko group, while the control groups slightly increased to 2.4 to 2.5.^56^ This was one of the relatively few trials reporting both allocation concealment and blinding of outcome assessors, although retention was somewhat lower in both control groups (82.5% and 73%) than the Buteyko group (90%).

Two other trials, both with fairly intensive interventions, reported standardized effect sizes greater than 1.2, which would generally be considered large.54,55 In the trial by Holloway and colleagues, for example, the Papworth intervention group participants showed 18- to 21-point improvements on the 100-point SGRQ symptom subscale, compared with two-point improvements in the control group at 6 and 12 month followup.55 This change is even greater than the change on the SGRQ seen in patients whose treatment was judged to be “very effective” in other research.45 Outcomes assessment was not blinded in this trial, which may have artificially increased the effect size if intervention participants were more prone to demand characteristics. On the other hand, this trial relied on an asthma registry to recruit patients and did not independently verify the asthma diagnosis with pulmonary function testing. As such, if some of the patients were misdiagnosed and actually had chronic obstructive pulmonary disease or another respiratory condition, then this would likely attenuate the intervention’s effect. The asthma registry approach likely increases the applicability to typical clinical settings.

Similarly, the trial conducted in Greece by Grammatopoulou and colleagues54 showed intervention participants moving from a score consistent with uncontrolled asthma to one in a range similar to those with completely controlled asthma at 26-week followup.96,97 The average control group score, on the other hand, remained below the average score of someone with well-controlled asthma.

The other fairly intensive trial, which was not included in the meta-analysis, reported mixed results, found differences in symptom scores from daily diaries, but no group differences in a standardized symptom scale.52 This was a fairly small trial (n=30 per group) with fairly low followup at 6 months (77% retention in the intervention group vs. 80% in the control group), using a last-observation-carried-forward (LOCF) data substitution method.

Of the remaining trials, which were all fairly low intensity, only one reported statistically significant improvements in symptoms, and only at four weeks.71 The other trials did not find improvements in asthma symptoms after 1 to 6 months.51,57,59 Other than the mouth-taping cross-over trial, these trials showed effect sizes consistent with small beneficial effects, but group differences were not statistically significant.

#### Medication Use

Medication use was reduced in three52,56,57 of the six trials reporting these outcomes (Table 4; Appendix D, Evidence Table 1d).51,52,56,57,59,71 However, medication use was reported in only two of the four higher-intensity trials.52,56 In the largest trial, reliever medication use dropped from 18 puffs per week at baseline in all groups to less than one puff per week in the intervention group, compared with no change in either of the control groups at 6-month followup.56 Although specific data were not shown, this trial also reported greater reductions in the use of controller medication. Although the data were self-reported, and may be subject to demand characteristics (since Buteyko participants were encouraged to delay bronchodilators), they were gathered by blind outcome assessors.

Reliever medication use was reduced at 6-month followup in the trial by Cooper and colleagues comparing a Buteyko intervention with a sham breathing retraining device.52 SABA use was reduced by a median of two puffs per day in the intervention group, compared to no change in the control group. Neither ICS use nor prednisone use differed at 6-month followup in this trial. After 6-month followup, 60 of the 69 participants completing the first phase of the trial took part in a steroid-reduction phase. Intervention participants in this phase reduced ICS use by a median of 41 percent, compared with no reduction in the control group. However, this difference was not tested directly; instead, the authors report only the results of the three-way comparison between the Buteyko group and another treatment arm (a device to control the pace of breathing), which was not statistically significant (p=0.70). This is the trial with fairly low and differential retention that used LOCF as a data substitution method. Medication use was not reported in the two other higher intensity trials that showed large positive effects on asthma symptoms.54,55

Medication outcomes were reported in the mouth-taping trial51 and the other three lower-intensity trials.57,59,71 Reductions in bronchodilator use in the trial of video-based instruction57 were similar to those seen in the trial by Cooper and colleagues.52 This was a small trial (n=36) with only 4 weeks of followup, but did have fairly high retention (89% in each group). This trial reported no group differences in ICS use. No group differences in medication use were seen in the mouth-taping trial51 or the lower-intensity Papworth-style interventions.59,71

#### Quality of Life and Functioning

Seven of the trials51,52,54,55,57,59,71 reported measures of asthma-related quality of life, functioning, or mental health symptomatology at 1 to 12 months post-baseline, and all but the one study51 (which focused only on mouth-taping) reported group differences in some measures (Appendix D, Evidence Table 1e).

##### Asthma-Related Quality of Life

Six trials51,52,55,57,59,71 reported asthma-specific quality of life using standardized measures, including only two of the higher-intensity trials (Table 4; Appendix D, Evidence Table 1e).52 Four reported statistically significant group differences at one or more time points. The trial with the higher-intensity Papworth intervention55 reported improvements on the SGRQ one year after the end of the intervention, however the differences appeared to be driven by the “symptoms” subscale, since neither the “impacts” nor the “activities” subscales showed group differences at either followup. Thus, improvements were seen in symptoms, but did not appear to affect other areas of day-to-day life. The remaining higher intensity trials either found no differences between groups52 or did not report this outcome.54,56 The three lower-intensity trials that reported group differences in a measure of quality of life up to 6 months post-baseline were the video-based treatment trial and both of the lower-intensity Papworth-style trials.57,59,71

##### Functioning and Mental Health

Changes in Short-Form Health Survey (SF-36) scores were reported in two trials, and although many SF-36 subscale outcomes were reported in these two trials, group differences were rarely seen (Appendix D, Evidence Table 1e).52,54 Two trials, including the Papworth intervention trial with a large effect on asthma symptoms,55 reported improvements in mental health outcomes of depression and anxiety at 26 weeks.55,59 Anxiety and depression scales scores indicated that participants were not, on average, anxious or depressed either before or after treatment. Reductions were small in magnitude (e.g., group differences of 1.6 on a 68-point rating scale). Group differences were maintained in one of these trials to 1 year.55

### Hyperventilation Reduction Breathing Techniques Versus Other Breathing Techniques

Key Points:

- Hyperventilation reduction breathing techniques may be more likely to reduce reliever medication use than other breathing techniques in adults, but strength of evidence is low.
- Hyperventilation reduction training is no more likely to improve symptoms, controller medication use, or quality of life than other breathing techniques functioning in adults, but strength of evidence is low.

Four RCTs (n=285) directly compared the use of breathing techniques targeting hyperventilation reduction with another breathing technique that did not target hyperventilation reduction. Three of these trials used the Buteyko approach50,52,53 and one was modeled after the Papworth method (Table 5; Appendix D, Evidence Tables 2a and 2b).58 One of these involved a 10-hour Buteyko intervention and was described above, compared to the use of a device to modify breathing to achieve a typical yoga inspiration-to-expiration cycle of 1:2 with minimal one-on-one instruction and no components addressed other than the breathing technique.52

The three remaining trials employed comparators targeting controlled or paced breathing, but did not encourage the use of slow, nasal, shallow breathing with breath-holding or other techniques focused on reducing hyperventilation.50,53,58 All of these trials involved at least five contacts, usually face-to-face. Two trials used an approach that was initially intensive, meeting every day for 5 to 7 days for training.50,53 All three trials attempted to provide the same frequency and hours of treatment in both treatment groups. However, in one trial more than half of the Buteyko participants received additional instruction sessions and the average number of followup phone calls was seven in the Buteyko group, compared to one in the comparison group.50

In addition to some kind of breathing retraining in the nonhyperventilation reduction groups, one trial also included general asthma education and relaxation techniques,50 and another included shoulder and upper arm stretches.58

All four trials were rated as fair quality (Table 11). One trial had a number of quality-related issues, despite having followup on 95 percent of participants, including only a small number of participants randomized (n=20 or fewer per group), a very wide age range (age 12 to 70 years), no information on blinding of outcomes assessment, and reliance on self-report of variability in breathing symptoms that improve with beta_2_-agonist use for asthma diagnosis.50 Additionally, the Buteyko intervention was more intensive than the comparator.

Table 11 Quality and applicability issues: hyperventilation reduction breathing techniques versus nonhyperventilation reduction breathing techniques

Study | Study Design | Followup | Group | N Randomized | Retention | Allocation Concealment | Blinding of Outcomes Assessment | PFT for Asthma Confirmation | Excluded Those With Other Resp. d/o | Handling of Missing Data | Overall Quality Rating^†^ | Other Quality Concerns or Clarifications | Factors Limiting Applicability to U.S. Health Care Settings
Bowler 1998^50,73,88^ | RCT | 13w | IG1 (BBT) | 19 | 95% | Yes | NR | No | Likely^*^ | None | + | IG1 more intensive | Conducted in Australia, all volunteer sample, used certified Buteyko practitioner, high levels of baseline asthma medication use
Bowler 1998^50,73,88^ | RCT | 13w | IG2 (abdom. breathing) | 20 | 95% | Yes | NR | No | Likely^*^ | None | + | IG1 more intensive | Conducted in Australia, all volunteer sample, used certified Buteyko practitioner, high levels of baseline asthma medication use
Cooper 2003^52^ | RCT | 26w | IG1 (BBT) | 30 | 77% | NR | Yes | Yes | Likely^*^ | LOCF | ++ | Unclear which baseline differences were controlled for | Conducted in the UK, used certified Buteyko practitioner for BBT intervention, used device that may not be widely available for yoga breathing device comparator
Cooper 2003^52^ | RCT | 26w | IG2 (yoga breathing device) | 30 | 73% | NR | Yes | Yes | Likely^*^ | LOCF | ++ | Unclear which baseline differences were controlled for | Conducted in the UK, used certified Buteyko practitioner for BBT intervention, used device that may not be widely available for yoga breathing device comparator
Cowie 2008^53^ | RCT | 26w | IG1 (BBT) | 65 | 86% | Yes | NR | Yes | Yes | None | ++ | Did not report beta_2_-agonist, use as outcome, but did report other medications; concern about reporting bias | Conducted in Canada, university setting, used certified Buteyko practitioner for BBT intervention, certified physical therapist of physical therapy intervention
Cowie 2008^53^ | RCT | 26w | IG2 (physiotherapy) | 64 | 98% | Yes | NR | Yes | Yes | None | ++ | Did not report beta_2_-agonist, use as outcome, but did report other medications; concern about reporting bias | Conducted in Canada, university setting, used certified Buteyko practitioner for BBT intervention, certified physical therapist of physical therapy intervention
Slader 2006^58^ | RCT | 28w | IG (BBT) | 28 | 82% | Yes | Yes | Yes | No, but limited to non-smokers with ≤ 10 pack-years | None for 28w | +++ | | Conducted in Australia, limited to those with moderate to severe asthma, low baseline scores on mood domains on quality of life questionnaire, conducted in research setting.
Slader 2006^58^ | RCT | 28w | IG2 (controlled breathing) | 29 | 86% | Yes | Yes | Yes | No, but limited to non-smokers with ≤ 10 pack-years | None for 28w | +++ | | Conducted in Australia, limited to those with moderate to severe asthma, low baseline scores on mood domains on quality of life questionnaire, conducted in research setting.

abdom: abdominal; BBT: Buteyko breathing technique; d/o: disorder(s); IG: intervention group; LOCF: last observation carried forward; NR: not reported; PFT: pulmonary function test; RCT: randomized controlled trial; UK: United Kingdom; US: United States; w: week(s)

* Did not specifically report excluding those with other respiratory disorders, but did report excluding those with other disorders without listed the specific disorders excluded.

† All trials were rated “Fair”; further gradation is provided as follows: +++ = Minor quality issues, but not meeting criteria for “Good” quality; ++ = Between +++ and + trials in quality; + = Substantial quality issues, but no clear fatal flaw

Another trial reported good measurement and randomization procedures, but was rated as “fair” quality because of the small number of participants (n=57 total) and retention below 90 percent.58 The remaining two failed to report either allocation concealment or blinding of outcomes assessment, and had either fairly high attrition overall52 or higher attrition in the Buteyko breathing technique group than the other intervention group,53 in addition to other minor issues.

These trials were conducted in Australia,50,58 the United Kingdom,52 and Canada.53 Average age ranged from 44 to 47, and all but one had a wide age range from 12 to 18 years up to 65 or older. Asthma severity was quite high in one trial, where participants were using an average of almost 900 mcg of reliever medication per day and 1,250 mcg of ICS (in beclomethasone equivalents).50 Baseline FEV_1_ was 74 percent in this trial. Participants in the remaining trials were using two to three puffs of reliever medication per day along with 650 to 850 mcg of ICS, with an average FEV_1_ around 80 percent.52,53,58

#### Asthma Symptoms

Two trials reported no group differences in asthma control, with little improvement in either group at 13 and 26 weeks (Table 5; Appendix D, Evidence Table 2c).50,53 Two reported no or minimal group differences but did report improvement in both treatment groups for either the asthma control questionnaire and physician global rating at 28 weeks58 or median change in the symptoms subscale of the Mini-AQLQ at 26 weeks.52 Within-group change in the latter was not tested statistically, but both groups showed a median improvement of more than 0.5, which is considered a clinically significant difference.98 The best quality trial in this group showed almost no group differences on five additional symptom scales; both groups improved on two of the additional symptom scales.58

#### Medication Use

Two50,52 of the three50,52,58 trials reporting reliever medication use found greater reductions with Buteyko breathing technique than either abdominal breathing50 or a device to train in the use of prolonged exhalation after 13 to 26 weeks (Table 5; Appendix D, Evidence Table 2d).52 The trial with the greatest baseline asthma severity (and the most quality concerns, including more intensive intervention contacts in the hyperventilation reduction group than the comparison breathing intervention) showed the greatest improvements in reliever use, reporting median reductions of 904 mcg per day in bronchodilator use at 3-month followup in the Buteyko group, compared with a 57 mcg reduction in the abdominal breathing group.50 The Buteyko group went from using approximately 9 to 10 puffs of beta_2_-agonist per day to approximately one puff every other day. The trial showing no group differences reported reductions in reliever medication by almost two puffs per day in both the hyperventilation-reduction group and the controlled breathing with stretching group.58

All four trials reported results for controller medication. Two trials reported little change in ICS use for either group,50,52 including the trial with the most dramatic results for beta_2_-agonists.50 Of the remaining trials, one reported that ICS use was reduced by 50 percent in both the Buteyko and the controlled breathing groups,58 and other trial reported greater reductions in ICS use and a greater likelihood of discontinuing long-acting beta_2_-agonists with hyperventilation reduction techniques than with a more typical physical therapeutic approach.53 In this trial, ICS use was reduced by an average of 317 mcg in the hyperventilation-prevention group and only 56 mcg in the physical therapy group. Two trials reported no differences between groups in prednisone use.50,52

#### Quality of Life and Functioning

All four trials reported an asthma-specific quality of life outcome, and none found that any group showed greater improvement than another group (Table 5; Appendix D, Evidence Table 2e). In two trials, both groups showed increases of more than 0.5 on the Juniper quality of life scales,52,53 which is the threshold for clinically significant change.45 However, the changes over time were statistically significant in only one of these two trials.53

One trial reported functioning outcomes and found that scores on the subscale role limitation due to physical problems improved by a median of 25 points on a 100-point scale at 3 months in the hyperventilation-prevention group, while the median change in the device-assisted yoga-style breathing was zero.52 Other functioning subscales showed little improvement in either group.

### Yoga Breathing Versus Control

Key Points:

- Yoga breathing may improve asthma symptoms and quality of life in adults, but strength of evidence is low due to concerns about the methodological quality of the trials.
- Evidence is insufficient to determine whether yoga can reduce asthma medication use in adults and children.

Five trials (n=360) compared the yoga group with a control group (Table 6; Appendix D, Evidence Table 3a).60–64 All were fairly to highly intensive interventions and all required daily practice at home in addition to supervised sessions (Appendix D, Evidence Table 3b). Two programs conducted in India were very intensive.60,64 One included 4-hour sessions daily for 2 weeks covering yoga practice, lectures, group discussions, diet (including a study-provided breakfast), and stress management, followed by an additional 4 weeks of home practice.64 Another trial involved a 70-minute-long daily yoga session for 6 months and all patient were hospitalized initially to facilitate training.60 The duration of the inpatient stay was not specified. This trial was limited to male vegetarians aged 25 to 50 years.

A third trial in India was focused specifically on yoga breathing exercises among people with at least 6 months of prior yoga experience, compared with the use of meditation.63 Both treatment arms involved 20 minutes of practice twice daily for 12 weeks, although the number of these sessions that were supervised versus those conducted at home was not described. In this study, the authors reported that participants “had no history of regular medication and they were advised to discontinue if on any medication.” It was unclear if this is referring to all medication, or only asthma medication. No age limits were reported and the average age in this trial was 29 years.

The final two trials were conducted in the United States.61,62 One compared an eight-session yoga class with a stretching class.62 This trial was limited to participants aged 18 and over, with an average age of 51 years. The other trial involved a comprehensive naturopathic treatment program that included yoga as well as dietary restriction, nutritional supplements, and a guided journaling session.61 Participants in this trial were predominantly female and the average age was 44 years.

All trials were rated fair quality and three had substantial quality issues that limit our confidence in results (Table 12).60,61,63 Two of these trials were quite intensive and conducted in India.60,63 These trials included only 17 to 25 people per group, failed to report both allocation concealment and blinding of outcomes assessment, and provided no information on refusals or exclusions prior to randomization. In addition, one did not indicate how they divided the participants into groups and failed to report the use of pulmonary-function testing to confirm reversibility for asthma diagnosis.60 Also, the usual-care group in this trial received only bronchodilators, antibiotics, and expectorants, but not ICS. The other trial did not report the proportion of participants with followup, and it was unclear if their group assignment was truly random.63 The third trial was conducted in the United States and involved a comprehensive naturopathic intervention, which did not allow us to determine the effect of yoga breathing techniques specifically.61 Outcomes assessment in this trial was not blinded, and it was unclear whether those assigning participants to groups had access to intake assessment data. This trial also did not report the use of pulmonary function testing in the diagnosis of asthma, number of refusals or exclusions prior to randomization, nor did they describe whether they excluded people with other respiratory disorders or recent use of oral steroids from their sample.

Table 12 Quality and applicability issues: yoga breathing techniques versus control

Study | Study Design | Followup | Group | N Randomized | Retention | Allocation Concealment | Blinding of Outcomes Assessment | PFT for Asthma Confirmation | Excluded Those With Other Resp. d/o | Handling of Missing Data | Overall Quality Rating^†^ | Other Quality Concerns or Clarifications | Factors Limiting Applicability to U.S. Health Care Settings
Khare 1991^60^ | RCT | 26w | IG (yoga breathing) | 17 | 100% | NR | NR | NR | Yes | NA | + | No description of refusals or exclusions prior to randomization | Conducted in India, limited to male vegetarians age 25 to 50, standard of care did not include ICS
Khare 1991^60^ | RCT | 26w | CG | 17 | 100% | NR | NR | NR | Yes | NA | + | No description of refusals or exclusions prior to randomization | Conducted in India, limited to male vegetarians age 25 to 50, standard of care did not include ICS
Kligler 2011^61^ | RCT | 26w | IG (yoga) | 77 | 87 | U | No | NR | NR | Yes, RER | + | Did not limit to those without recent oral steroid use, no description of refusals or exclusions prior to randomization | Self-selected participants, Included dietary and journaling treatment components
Kligler 2011^61^ | RCT | 26w | CG | 77 | 80 | U | No | NR | NR | Yes, RER | + | Did not limit to those without recent oral steroid use, no description of refusals or exclusions prior to randomization | Self-selected participants, Included dietary and journaling treatment components
Sabina 2005^62^ | RCT | 16w | IG (yoga breathing) | 29 | 79% | Yes | Yes | Yes | Yes | Yes, Method NR | ++ | None | Mild to moderate asthma only, self-selected sample, conducted in research setting
Sabina 2005^62^ | RCT | 16w | CG | 33 | 67% | Yes | Yes | Yes | Yes | Yes, Method NR | ++ | None | Mild to moderate asthma only, self-selected sample, conducted in research setting
Saxena 2009^63^ | RCT | 12w | IG (yoga breathing) | 25 | NR | NR | NR | Yes | Yes | NR | + | Randomization procedures likely not truly random, no description of refusals or exclusions prior to randomization | Conducted in India, limited to those with 26w experience with yoga, limited to those with no regular use of medication or advised to discontinue medication if using
Saxena 2009^63^ | RCT | 12w | CG | 25 | NR | NR | NR | Yes | Yes | NR | + | Randomization procedures likely not truly random, no description of refusals or exclusions prior to randomization | Conducted in India, limited to those with 26w experience with yoga, limited to those with no regular use of medication or advised to discontinue medication if using
Vempati 2009^64,74,83–87^ | RCT | 8w | IG (yoga breathing) | 30 | 97% | NR | NR | Yes | Yes | None | ++ | None | Conducted in India, mild to moderate asthma only
Vempati 2009^64,74,83–87^ | RCT | 8w | CG | 30 | 93% | NR | NR | Yes | Yes | None | ++ | None | Conducted in India, mild to moderate asthma only

CG: control group; d/o: disorder(s); ICS: inhaled corticosteroids; IG: intervention group; LOCF: last observation carried forward; NA: not applicable; NR: not reported; PFT: pulmonary function test; RCT: randomized controlled trial; RER-Random Effects Regression model; UK: United Kingdom; US: United States; w: week(s)

* Did not specifically report excluding those with other respiratory disorders, but did report excluding those with other disorders without listed the specific disorders excluded.

† All trials were rated “Fair”; further gradation is provided as follows: +++ = Minor quality issues, but not meeting criteria for “Good” quality; ++ = Between +++ and + trials in quality; + = Substantial quality issues, but no clear fatal flaw

The Indian trial of daily 4-hour sessions also failed to report both allocation concealment and blinding of outcomes assessment, but had retention above 90 percent in both groups and good assessment procedures.64 The U.S.-based yoga class trial had the best methods of the group, but had low and somewhat differential retention (79% in the intervention group vs. 67% in the control group).62

Asthma severity was not consistently described in this subgroup of studies, but average severity would likely be considered to be moderate according to National Asthma Education and Prevention Program (NAEPP) as based on either daily reliever use62 or FEV_1_ in the “moderate asthma” range.

#### Asthma Symptoms

All but one trial62 showed greater improvement in the yoga groups on at least one measure of asthma symptoms, including all three trials conducted in India (Table 6; Appendix D, Evidence Table 3c).60,61,63,64 The U.S.-based trial of an eight-session yoga class reported no group differences in asthma symptoms.62 Although it was difficult to compare effect sizes across different measures, the largest effect size appeared to be found in one of the lower quality trials based in India, comparing yoga breathing exercises with meditation.63 This trial reported a 64 percent reduction in symptoms in the intervention group at 12 weeks, compared with a six percent reduction in symptoms in the meditation group.

Another trial with a very intensive intervention reported a very large effect size at 2- and 4-week followup, but the effect was attenuated (yet still statistically significant) after 8 weeks.64 In this trial and the U.S.-based trial of a comprehensive naturopathic intervention,61 both groups showed improvements in a Juniper symptom subscale well beyond the level of clinical significance (i.e., improvement of 0.5 points).45 Greater improvements were apparent, however, in those participating in the yoga interventions than those in the control groups.

#### Medication Use

Three trials reported medication use,60,62,64 including two trials conducted in India (Table 6; Appendix D, Evidence Table 3d).60,64 One trial found that 53 percent of yoga participants reduced medication required to control their dyspnea, compared with 18 percent in the control group after 26 weeks, but the specific type of medication was not reported.60 In the trial of daily 4-hour yoga sessions, as with asthma symptoms, both groups showed improvement in medication use: yoga participants reduced rescue medication use by an average of 1.5 puffs per day after 8 weeks compared with a reduction of 0.5 puffs per day among control participants.64 There were no statistically significant group differences between those taking the yoga class and those on the waiting list after 16 weeks.62

#### Quality of Life and Functioning

Three of the trials reported functioning or quality of life outcomes (Appendix D, Evidence Table 3e).61,62,64 The pooled standardized effect size for overall asthma-related quality of life in these three trials was 0.66 (95% CI, 0.21 to 1.10, I^2^=59.3%, Figure 4), consistent with improved asthma-related quality of life in yoga breathing groups compared to controls.

Figure 4 Effect of yoga breathing techniques on quality of life at 2 to 6 months

CI: confidence interval; est: estimated; IG: intervention group; N: sample size; SD: standard deviation; SMD: standardized mean difference

Figure 4 displays a forest plot of the standardized pooled effect or standardized mean difference (SMD) of three yoga breathing trials (versus control) on asthma-related quality of life. The SMD for overall asthma-related qualtiy of life in these three trials was 0.66 (95% CI, 0.21 to 1.10, I2=59.3%), meaning that intervention participants showed greater improvements in asthma-related quality of life than control participants..

The eight-session yoga class did not lead to greater improvement in overall asthma-related quality of life than being on a waiting list after 16 weeks.62 Participants in both the comprehensive naturopathic intervention61 and the daily 4-hour sessions64 showed greater improvement overall asthma-related quality of life (again exceeding the threshold for clinically significant improvement) as well as the “activities” and “emotions” subscales than the usual care groups after 8^64^ and 26 weeks.61 As before, however, the usual-care participants also showed clinically and statistically significant improvement in both of these trials. There were also group differences on the SF-36 subscales of physical and social functioning, role limitations due to physical limits, and both of the summary component scores (physical and mental) in the trial involving a comprehensive naturopathic treatment program.61

### Inspiratory Muscle Training Versus Control

Key Points:

- Evidence is insufficient to draw conclusions about the effect of IMT on asthma symptoms, medication use, or quality of life in adults and children.

Five small trials (n=169) examined the effect of IMT on asthma (Table 7; Appendix D, Evidence Tables 4a and 4b) after 8 to 26 weeks.65–69 Three of these trials, all conducted by the same researcher in Israel, compared the use of a training device that controlled the level of resistance associated with inhalation with a sham device that provided no resistance.67–69 Level of resistance was gradually increased over the course of training with the active device, but the sham device provided no resistance at any setting. Participants’ average age ranged from 34 to 40 years, and no age limitations were listed for any of these trials. One trial was limited to women categorized as being in the mild-persistent to moderate range of asthma. Participants used an average of 3.2 puffs per day of reliever medication and had a baseline FEV_1_ of 83 percent.68 The second trial was limited to those using two or more puffs of SABA daily, with an average use of 2.7 puffs of reliever per day and a baseline FEV_1_ of 91 percent.69 The third trial was limited to people with severe asthma. Participants in this trial used an average of six puffs of reliever medication per day and had an average baseline FEV_1_ of 59 percent, the lowest of all included trials.67

The fourth trial was conducted among children in Brazil who had previously received no treatment for asthma and whose asthma was poorly controlled.65 Baseline FEV_1_ was not reported in this trial. The trial compared a 14-session program that included one-on-one instruction as well as IMT with the use of a breathing training device that built up inspiratory muscles through gradually increasing the resistance required for inspiration, plus medication (rescue and preventive) and three monthly medical visits for medication monitoring and general asthma education. This was compared with asthma education and medication alone.

The final trial was conducted in South Africa among inactive nonsmokers with moderate-persistent asthma and an average age of 22 years.66 This trial instructed participants in diaphragmatic breathing. Participants were told to hold a weight on their abdomen while breathing through a 1 centimeter wide tube. Control group participants received no breathing training.

All trials were rated fair quality, and all but one67 had fairly substantial quality issues (Table 13).65,66,68,69 The trials conducted in Israel included 15 or fewer participants per treatment group in all cases,67–69 although followup rates where high in two of the three trials.67,69 None of these trials reported whether allocation was concealed or whether they excluded participants with other respiratory disorders. None of these trials provided detailed inclusion/exclusion criteria and two them also failed to report information on baseline comparability of the treatment groups.68,69

Table 13 Quality and applicability issues: inspiratory muscle training versus control

Study | Study Design | Followup | Group | N Randomized | Retention | Allocation Concealment | Blinding of Outcomes Assessment | PFT for Asthma Confirmation | Excluded Those With Other Resp. d/o | Handling of Missing Data | Overall Quality Rating^†^ | Other Quality Concerns or Clarifications | Factors Limiting Applicability to U.S. Health Care Settings
Lima 2008^65^ | RCT | 13w | IG (IMT) | 25 | 100% | NR | NR | No | NA | NA | + | Assessment of symptoms and medication use not described | Conducted in Brazil, limited to 8- to 12-year-old children with untreated, uncontrolled asthma
Lima 2008^65^ | RCT | 13w | CG | 25 | 100% | NR | NR | No | NA | NA | + | Assessment of symptoms and medication use not described | Conducted in Brazil, limited to 8- to 12-year-old children with untreated, uncontrolled asthma
Shaw 2011^66,91^ | RCT | 8w | IG (abdominal strengthening) | 22 | 100% | NR | NR | Yes | NR | NA | + | Did not report asthma sx or medication use, no description of refusals or exclusions prior to randomization | Conducted in South Africa, did not describe recruitment source, did not describe baseline asthma sx, or med use, University setting with average age 21
Shaw 2011^66,91^ | RCT | 8w | CG | 22 | 100% | NR | NR | Yes | NR | NA | + | Did not report asthma sx or medication use, no description of refusals or exclusions prior to randomization | Conducted in South Africa, did not describe recruitment source, did not describe baseline asthma sx, or med use, University setting with average age 21
Weiner 1992^67^ | RCT | 26w | IG (IMT) | 15 | 100% | NR | Yes | Yes | NR | NA | ++ | Did not provide detailed inclusion/exclusion rules; noted that “most patients in the control group became gradually aware of the fact that they were using a sham device,” no description of refusals or exclusions prior to randomization | Conducted in Israel, limited to those with moderate to severe asthma
Weiner 1992^67^ | RCT | 26w | CG | 15 | 100% | NR | Yes | Yes | NR | NA | ++ | | Conducted in Israel, limited to those with moderate to severe asthma
Weiner 2000^69^ | RCT | 26w | IG (IMT) | 12 | 92% | NR | NR | Yes | NR | None | + | Did not provide detailed inclusion/exclusion rules; no information on baseline comparability of groups | Conducted in Israel, limited to those with > 1 puff/d beta_2_-agonist consumption
Weiner 2000^69^ | RCT | 26w | CG | 11 | 100% | NR | NR | Yes | NR | None | + | Did not provide detailed inclusion/exclusion rules; no information on baseline comparability of groups | Conducted in Israel, limited to those with > 1 puff/d beta_2_-agonist consumption
Weiner 2002^68^ | RCT | 20w | IG (IMT) | 11 | 91% | NR | Yes | Yes | NR | None | + | Did not provide detailed inclusion/exclusion rules; no information on baseline comparability of groups, no description of refusals or exclusions prior to randomization | Conducted in Israel, limited to females with mild to moderate asthma
Weiner 2002^68^ | RCT | 20w | CG | 11 | 82% | NR | Yes | Yes | NR | None | + | Did not provide detailed inclusion/exclusion rules; no information on baseline comparability of groups, no description of refusals or exclusions prior to randomization | Conducted in Israel, limited to females with mild to moderate asthma

* Did not specifically report excluding those with other respiratory disorders, but did report excluding those with other disorders without listed the specific disorders excluded.

† All trials were rated “Fair”; further gradation is provided as follows: +++ = Minor quality issues, but not meeting criteria for “Good” quality; ++ = Between +++ and + trials in quality; + = Substantial quality issues, but no clear fatal flaw

abdom: abdominal; CG: control group; d/o: disorder(s); IG: intervention group; IMT: inspiratory muscle training; NA: not applicable; NR: not reported; PFT: pulmonary function test; RCT: randomized controlled trial; US: United States; w: week(s)

The trials in South Africa66 and Brazil65 were also fairly small including 22 to 25 participants per treatment arm with 100 percent followup. Neither trial, however, reported allocation concealment or blinding of outcomes assessment. In addition, the Brazilian trial did not appear to use pulmonary testing to confirm asthma diagnosis, provided little detail on their outcomes assessment methods, and they did not report whether IMT trainers were in contact with the larger asthma treatment team (and perhaps providing advice or support for general asthma management and medication use such as encouraging patients to use controllers consistently) as part of the fourteen IMT-focused sessions.65 In addition, children receiving only asthma education and medication showed little improvement, which suggests these treatments were suboptimal. The South African trial did report the use of pulmonary testing to confirm asthma diagnosis, but provided no description of refusals and exclusions prior to randomization.66 They also reported no information on changes in asthma symptoms, medication use, or quality of life, but only reported pulmonary function outcomes.

#### Asthma Symptoms

Only two of the trials reported asthma symptoms at followup (Table 7; Appendix D, Evidence Table 4c).65,67 The Brazilian trial reported that all of the children in the control group regularly experienced daytime symptoms after 3 months, compared with none of the children receiving IMT.65 Similarly, 22 of the 25 control group children experienced frequent asthma attacks, compared with only two of the 25 IMT participants.65 Large group differences were also found for nighttime symptoms. The fact that the children receiving only medication management and asthma education were still experiencing high levels of asthma symptoms suggests that their treatment was not effective and may not have been comparable to treatment in the United States.

The Israeli trial with the fewest quality concerns reported greater improvement in morning chest tightness, cough, daytime asthma symptoms, and nighttime asthma symptoms after 6 months in IMT participants as recorded in daily diaries, compared with those using a sham device.67

#### Medication Use

Four trials reported some kind of group difference in change in bronchodilator use (Table 7; Appendix D, Evidence Table 4d).65,67–69 As with asthma symptoms, medication effects were large in the Brazilian trial: at 3-month followup 16 percent of the children in the IMT group were using bronchodilators compared with 84 percent of the control group children.65 They did not report on controller medication use, which is unfortunate since the children in both groups were previously untreated, initiating both rescue and controller medication in this trial, and we cannot tell if the level of recommended controller medication use was comparable between groups.

All three Israeli trials reported statistically significant reduction in beta_2_-agonist use at final followup in those using the active training device, but no such change in those who used the sham device after 13 to 26 weeks.67–69 Groups were not statistically compared directly with each other in two cases,68,69 however, and in one of these that provided sufficient data to calculate a standardized effect size, the effect was not statistically different from zero.69

#### Quality of Life

Two trials reported functioning outcomes (Appendix D, Evidence Table 4e).65,67 The Brazilian trial reported that none of the children undergoing IMT had difficulty with activities of daily living at 3-months followup, but all of the control children did.65 One of the Israeli trials reported an average decline of 1.7 days of missed work in the prior three months, compared with almost no change in the control group participants.67

### Other Nonhyperventilation Reduction Breathing Techniques Versus Control

Key Points:

- Evidence is insufficient to draw conclusions about the effect of other nonhyperventilation reduction breathing techniques on asthma symptoms, medication use, or quality of life in adults and children.

Two heterogeneous trials (n=153) compared a nonhyperventilation reduction breathing technique with a control group (Table 8; Appendix D, Evidence Tables 5a and 5b).52,70 One trial, conducted in the United States with paid volunteers, examined the use of biofeedback for breathing retraining.70 The intervention group engaged in biofeedback targeting respiratory resistance, respiratory reactance, and HRV as well as training in pursed-lip abdominal breathing with prolonged exhalation. This trial had three different control groups: biofeedback targeting only HRV, placebo biofeedback involving bogus “subliminal suggestions designed to help asthma,” and waiting list. The first three groups involved weekly biofeedback sessions for 10 weeks, plus the request to practice at home 20 minutes twice daily with a home-training unit. The trial did not report baseline medication use or FEV_1_ values, but reported that participants’ asthma was most commonly rated as being in the moderate persistent range based on medication level according to National Health, Lung and Blood Institute (NHLBI) criteria.1

The other trial compared the use of a device to modify breathing to achieve an inspiration-to-expiration cycle of 1:2 with a sham device that did not modify breathing.52 Comparisons involving other treatment arms in this trial were included above under hyperventilation reduction techniques. Participants were expected to practice using the device at home twice a day for six months. The average age of participants for this trial was 44 years, and was limited to participants aged 18 to 70 years. Both trials were rated as fair quality (Table 14). The main concerns of the biofeedback trial included lack of information on allocation concealment, higher retention in the wait list group than all other groups (92% vs. 74% to 79%), and fairly small sample size (22 to 25 per group), although they did report blinded outcomes assessment.70 The trial examining the breathing device had fairly low and somewhat differential retention (73% in the intervention group vs. 83% in the control group), conducted many statistical comparisons for the relatively small sample, and did not clearly describe whether baseline differences were controlled for, but did report blinded outcomes assessment.52 Both trials reported pulmonary function testing to confirm asthma diagnosis.

Table 14 Quality and applicability issues: other nonhyperventilation reduction breathing techniques versus control

Study | Study Design | Followup | Group | N Randomized | Retention | Allocation Concealment | Blinding of Outcomes Assessment | PFT for Asthma Confirmation | Excluded Those w/Other Resp. d/o | Handling of Missing Data | Overall Quality Rating^†^ | Other Quality Concerns Or Clarifications | Factors Limiting Applicability to U.S. Health Care Settings
Cooper 2003^52^ | RCT | 26w | IG2 (yoga breathing device) | 30 | 73% | NR | Yes | Yes | Likely^*^ | LOCF | ++ | Unclear which baseline differences were controlled for | Conducted in the UK, used device that may not be widely available
Cooper 2003^52^ | RCT | 26w | CG | 30 | 80% | NR | Yes | Yes | Likely^*^ | LOCF | ++ | Unclear which baseline differences were controlled for | Conducted in the UK, used device that may not be widely available
Lehrer 2004^70,76,90^ | RCT | 12w | IG (abdom. breathing with biofeedback | 23 | 74% | NR | Yes | Yes | Yes | LOCF | ++ | No description of refusals or exclusions prior to randomization | All volunteer sample, might have higher standard of care since research protocol stipulated strict adherence to NAEPP guidelines with monthly visits, conducted in research setting
Lehrer 2004^70,76,90^ | RCT | 12w | CG1 (biofeedback) | 22 | 77% | NR | Yes | Yes | Yes | LOCF | ++ | No description of refusals or exclusions prior to randomization | All volunteer sample, might have higher standard of care since research protocol stipulated strict adherence to NAEPP guidelines with monthly visits, conducted in research setting
Lehrer 2004^70,76,90^ | RCT | 12w | CG2 (placebo) | 24 | 79% | NR | Yes | Yes | Yes | LOCF | ++ | No description of refusals or exclusions prior to randomization | All volunteer sample, might have higher standard of care since research protocol stipulated strict adherence to NAEPP guidelines with monthly visits, conducted in research setting
Lehrer 2004^70,76,90^ | RCT | 12w | CG3 (waitlist) | 25 | 92% | NR | Yes | Yes | Yes | LOCF | ++ | No description of refusals or exclusions prior to randomization | All volunteer sample, might have higher standard of care since research protocol stipulated strict adherence to NAEPP guidelines with monthly visits, conducted in research setting

abdom: abdominal; CG: control group; d/o: disorder(s); IG: intervention group; LOCF: last observation carried forward; NAEPP: National Asthma Education and Prevention Program; NR: not reported; RCT: randomized controlled trial; PFT: pulmonary function test; UK: United Kingdom; US: United States; w: week(s)

* Did not specifically report excluding those with other respiratory disorders, but did report excluding those with other disorders without listed the specific disorders excluded.

† All trials were rated “Fair”; further gradation is provided as follows: +++ = Minor quality issues, but not meeting criteria for “Good” quality; ++ = Between +++ and + trials in quality; + = Substantial quality issues, but no clear fatal flaw

The comparison between the active biofeedback groups targeting breathing in addition to HRV versus HRV-only tests the unique contribution of breathing retraining.70 No differences were found between these groups on either asthma symptoms or controller medication use at 12 weeks. Both of these two groups, however, did show greater reductions in number of asthma exacerbations and controller medication use than the placebo and waitlist groups, suggesting biofeedback targeting HRV may have contributed to improvement in asthma. This trial did not examine quality or life or functioning.70

No differences on asthma symptoms, medication use or quality of life were noted at 6-month followup in the trial comparing the device to train prolonged exhalation with a placebo device.52

## Key Question 1a Does the efficacy and/or effectiveness of breathing techniques for asthma health outcomes differ between different subgroups (e.g., adults/children; males/females; different races or ethnicities; smokers/nonsmokers; various types and severities of asthma; and/or different coexisting conditions)?

Key Points:

- Evidence is insufficient to determine whether patient characteristics influence treatment effect in adults and children.

The trials were heterogeneous on too many factors and reporting was too inconsistent to allow us to assess the impact of population characteristics such as demographic characteristics or baseline asthma severity on effect size across studies. However, three trials did report results of subgroup analyses examining differential effects of treatment by different characteristics.51,59,90 It was unclear if these analyses were planned a priori, but they do target subgroups hypothesized to gain the greatest benefit from the specific interventions of their trials, based on the physiologic models of action for their interventions or prior research. None of the trials reported conducting tests for interactions before exploring subgroup analyses. The United Kingdom trial that compared a relatively low-intensity Papworth-style intervention with an asthma education comparator of comparable intensity found that results were consistent between those who scored in the “disordered breathing” range on the Nijmegen questionnaire and those who did not.59 Similarly, the trial of nighttime mouth-taping did not find larger effect among the subgroup of people who were rated as being “mouth breathers” at baseline.51 Finally, the trial using biofeedback for breathing retraining found that there were no differences in response between those older than 40 years of age and those younger than 40 years of age.90

## Key Question 1b Does the efficacy and/or effectiveness of breathing techniques for asthma health outcomes differ according to variations in implementation (e.g., trainer experience) and/or nonbreathing components of the intervention (e.g., anxiety management)?

Key Points:

- Evidence is insufficient to determine whether certification and/or training of the provider affects effect size in hyperventilation reduction trials in adults and children.
- Exploratory analyses suggest that comprehensive approaches, especially those including additional, nonbreathing components may be more likely to show a benefit than approaches that isolate a single aspect of breathing in adults.
- Exploratory analyses suggest that intensity-matched control groups and control groups that involved either an alternate breathing approach or a technique to reduce autonomic arousal may reduce the likelihood of finding group differences in adults.

Among the 11 hyperventilation reduction trials, the expertise of the trainer may have had an impact on medication use, but not on self-reported symptoms. Four of the hyperventilation reduction trials reported using providers with specific training or certification in the Buteyko breathing technique, three trials described their intervention as Buteyko, but did not involve a practitioner, either because they used video tapes to deliver the intervention57,58 or limited the intervention to mouth-taping.51 Four trials used physical therapists without describing further certification, and did not describe their method as Buteyko.54,55,59,71 All four hyperventilation reduction trials using specially training or certified providers showed reductions in medication use.50,52,53,56 Only one other trial showed reduction in medication use and only for controller use.57 However, the effect of practitioner training was not evident for self-reported symptoms: two52,56 of the four using Buteyko practitioners reported positive or mixed findings, compared with three54,55,71 of the seven trials that did not. Also, of the two trials reporting large improvements in asthma symptoms, one used certified Buteyko practitioners and one did not. Interestingly, the only trials reporting improvements in quality of life did not involve certified Buteyko practitioners.57,59

Looking across all trials, we compared the proportion of trials reporting benefits of treatment with and without several treatment components. First, interventions that included co-interventions in addition to breathing retraining52,55,61,64 (e.g., dietary advice, relaxation training) were likely to show a benefit, and interventions that provided comprehensive training and education on breathing retraining were more likely to show a benefit than interventions that isolated one aspect of breathing retraining (e.g., prolonged exhalation,52,70 mouth taping,51 strengthening inspiratory muscles67–69), which generally showed no benefit. For example, 83 percent of trials reporting extra non-breathing components reported a positive effect on asthma symptoms and 100 percent reported reductions in reliever medication use (of those reporting these outcomes), compared with 36 and 33 percent respectively among trials that restricted their interventions to breathing training. However, as discussed next, intensity of intervention (measured in hours of contact) and comprehensiveness (measured in number of intervention components) are likely confounded.

More comprehensive programs were also more likely to offer more hours of exposure to interventionists, and data were insufficient to truly tease apart the effects of hours of contact from the effects of the content that was presented. However, we were able to compare patterns of results among the 13 trials that had the same number of contact hours in the treatment and comparator groups52,53,56–59,62,63,67–71 with the 10 trials in which intervention participants received more hours of contact than those in the comparator group.50–52,54,55,60,61,64–66 Based on the number of trials reporting positive results (and not magnitude of effects), trials that matched intensity between treatment groups were less likely to show reductions in reliever medication use (83% of trials with more intensive intervention than control groups showed reductions in reliever use, compared with 30% of those with matching intensity in the two groups). However, comparable differences were not seen for asthma symptoms or quality of life outcomes. This exploratory analysis is limited by incomplete and perhaps selective reporting of these major outcomes.

Trials that compared any breathing retraining with either another breathing technique or an intervention likely to induce relaxation or a reduced state of autonomic arousal50,52,53,57,58,62,63,70 (k=8) were less likely to show group differences on asthma symptoms and quality of life compared with trials containing control groups that did not include either of these components (k=15).51,52,54–56,59–61,64--69,71 Seventy-five percent of trials with a nonbreathing or nonrelaxation comparator showed greater improvement on a measure of asthma symptoms in the intervention than the control group, compared with 12.5 percent of those with breathing or relaxation comparators. Similar results were seen for quality of life in these trials (20% showing benefit when compared with another breathing technique and/or relaxation vs. 57% showing benefit when compared with nonbreathing/relaxation control). We saw no qualitative relationship between likelihood of effect and study quality rating or whether the treatment involved the use of a device. These data are purely exploratory and do not account for magnitude or precision of effect, and they do not consider the impact of incomplete and perhaps selective reporting. As such, these data must be interpreted cautiously.

## Key Question 2 In adults and children 5 years of age and older with asthma, does the use of breathing exercises and/or retraining techniques improve pulmonary function or other similar intermediate outcomes when compared with usual care and/or other breathing techniques alone or in combination with other intervention strategies?

### Hyperventilation Reduction Breathing Techniques Versus Control Group

Key Points:

- Evidence is moderate that hyperventilation reduction breathing techniques do not improve lung function in adults.

Seven of the eight hyperventilation reduction trials reported one or more pulmonary function outcomes, primarily FEV_1_, FVC, and PEF at 4 to 52 weeks (Table 4; Appendix D, Evidence Table 1f).51,52,54–57,59 The standardized pooled effect size of five trials that could be combined showed minimal impact of hyperventilation reduction techniques on FEV_1_ (SMD=0.18, 95% CI, 0.00 to 0.37, I^2^=18.4%, Figure 5).52,54–56,59 Absolute changes in the interventions in these groups were small, for example improvements of 20 milliliters or less in FEV_1_ or less than 2 percent improvement in percent predicted of FEV_1_. The two trials that could not be pooled were the video-based interventions with matched-intensity control video for comparison, and the mouth-taping trial. Both found no effect of the intervention on FEV_1_.51,57

Figure 5 Effect of breathing retraining for asthma on pulmonary function at 1 to 6 months

CG: control group; CI: confidence interval; est: estimated; IG: intervention group; N: sample size; SD: standard deviation; SMD: standardized mean difference

Figure 5 displays a forest plot of the standardized pooled effect or standardized mean difference (SMD) of three groups on pulmonary function testing: hyperventilation reduction versus control (n=5), hyperventilation reduction versus other breathing techniques (n=3), and yoga breathing versus control (n=3). The SMD of the five hyperventilation reduction versus control trials showed minimal impact on FEV1 (SMD=0.18, 95% CI, 0.00 to 0.37, I2=18.4%). The SMD of the three hyperventilation reduction versus other breathing techniques trials was 0.02 (95% CI, −0.29 to 0.26, I2=0.0%), meaning no differences between groups. The SMD of the three yoga breathing trials versus control show greater improvements in lung function in intervention participants than control participatns (SMD=1.07, 95% CI, 0.072 to 1.43, I2=0.0%).

Group differences were only found in one trial, and only when compared to one of the two control groups.56 In this trial, percent predicted FEV_1_ increased from 80 to 81 percent in the Buteyko group while dropping from 75 to 74 percent in the nurse education control group. However, the lower-intensity control group of asthma education only (which was not included in the meta-analysis) did not show a drop and did not differ from the Buteyko group in change from baseline.

Three trials measured end-tidal CO_2_,54,55,59 which is a specific target of interventions to reduce hyperventilation. Only one trial found group differences, reported at 4, 12, and 26 weeks.54 Breathing rate was reduced in two of these trials, which suggests that participants did modify their breathing as instructed, but that modification did not always alter the CO_2_ levels as hypothesized by the Buteyko method proponents.54,55

### Hyperventilation Reduction Breathing Techniques Versus Other Breathing Techniques

Key Points:

- Hyperventilation reduction breathing techniques do not differ from other breathing techniques in terms of effect on pulmonary function in adults, but the evidence to support this is low.

All four trials in this group reported on change in FEV_1_ at 13 to 28 weeks (Appendix D, Evidence Table 2f). None found group differences, and there was little change within groups in any trials. The standardized pooled effect size of the three trials that provided sufficient data for analysis was −0.02 (95% CI, −0.29 to 0.26, I^2^=0.0%, Figure 5).50,52,53 Only one trial reported PEF, and found no group differences.50 Other measures of pulmonary function similarly showed no group differences including end-tidal CO_2_,50,58 provocative dose of methacholine causing 20 percent reduction in FEV_1_,52 and FVC.58 One trial did find that those undergoing Buteyko breathing technique had lower minute volume, a specific target of hyperventilation-reduction approaches, than those being trained in abdominal breathing.50 Thus, participants did modify their breathing in a manner consistent with the Buteyko breathing technique approach, but this change did not alter the amount of CO_2_ in their exhalation, which suggests that CO_2_ levels may not be an important trigger for asthma as suggested by Buteyko breathing technique proponents.

### Yoga Breathing Versus Control

Key Points:

- Yoga breathing techniques may improve pulmonary function in adults, but the evidence to support this is low.

Neither of the U.S.-based trials improved pulmonary function outcomes,61,62 despite the positive effects on other outcomes for the comprehensive naturopathic treatment program (Table 6; Appendix D, Evidence Table 3f).61 However, intensive yoga training in India resulted in substantial improvements in pulmonary function with a standardized pooled effect size for these three trials of 1.07 (95% CI, 0.72 to 1.43 I^2^=0.0%, Figure 5).60,63,64 The trial with the largest effect (and the greatest quality concerns) showed improvement in percent predicted FEV_1_ of 12 percentage points, compared with only two percentage points in the control group.63 The best-quality trial of the three Indian trials reported improvements of 7.7 percentage points in the intervention group on percent predicted FEV_1_ compared with a 2.6 percentage point reduction in the control group at eight-week followup.64 Group differences were also found on FVC,60 FEV_1_/vital capacity (VC) ratio,60,64 and PEF readings60,63,64 in the trials conducted in India, but not in those conducted in the United States.61,62 Only one of the trials reported that outcomes assessment was blinded.62 None of the trials described training or quality assurance measures for the spirometry technicians, and only one provided any detail about spirometry procedures beyond naming the machine that was used. The best-quality intensive India-based trial64 reported taking the best of three FEV_1_ readings, in accordance with ATS standards.11

### Inspiratory Muscle Training Versus Control

Key Points:

- Evidence is insufficient to determine whether IMT improves pulmonary function in adults and children.

Results from IMT trials were mixed and could not be pooled due to substantial differences in population, setting, and treatment approach in the three trials reporting the same outcome. Treatment-naïve Brazilian children with previously uncontrolled asthma improved PEF readings by an average of 80 percent after 3 months of IMT training along with asthma medication management and education, compared to almost no change on average in those receiving medication and asthma education alone (Table 7; Appendix D, Evidence Table 4f).65 Lack of improvement in the control group suggests that medication management may have been suboptimal in this group. Among adults, two trials showed improvements in both FEV_1_ and FVC, one with the use of an IMT device,67 and the other using weights placed on the abdomen while in a semi-recumbent position.66 Another trial found no differences in FEV_1_.68

### Other Nonhyperventilation Reduction Breathing Techniques Versus Control

Key Points:

- Evidence is insufficient to determine whether other nonhyperventilation reduction techniques improve pulmonary function in adults and children.

Spirometry results did not change over time in either the trial of prolonged exhalation using a training device52 or in any of the treatment groups in the biofeedback trial (Appendix D, Evidence Table 5f).70

## Key Question 2a Does the efficacy and/or effectiveness of breathing techniques for other asthma outcomes differ between different subgroups (e.g., adults/children; males/females; different races or ethnicities; smokers/nonsmokers; various types and severities of asthma; and/or different coexisting conditions)?

Key Points:

- Evidence is insufficient to determine whether patient characteristics influence the effect of treatment on pulmonary function in adults and children.

The best-quality trial of yoga conducted in India displaying large benefits of treatment reported that participants with exercise-sensitive asthma showed a greater improvement on FEV_1_ than those whose asthma was not sensitive to exercise.64 This analysis did not appear to be planned a priori, nor did the intervention particularly target factors that purported to differentially affect those with exercise-sensitive asthma. No other trials reported subgroup analyses for any pulmonary function outcomes.

## Key Question 2b Does the efficacy and/or effectiveness of breathing techniques for other asthma outcomes differ according to variations in implementation (e.g., trainer experience) and/or nonbreathing components of the intervention (e.g., anxiety management)?

Key Points:

- Evidence is insufficient to determine whether certification and/or training of the provider affects effect size in hyperventilation reduction trials.
- Exploratory analyses suggest that control groups that involved either an alternate breathing approach or a technique to reduce autonomic arousal may reduce the likelihood of finding group differences in adults.

Benefits were more likely to be seen if the control group did not involve breathing training of any kind or relaxation techniques (42% positive vs. 14% positive with breathing/relaxation comparison group). These data are preliminary, however, and only valid for hypothesis generation and did not account for effect size.

## Key Question 3 What is the nature and frequency of serious adverse effects of treatment with breathing exercises and/or retraining techniques, including increased frequency of acute asthma exacerbations?

Key Points:

- Hyperventilation reduction breathing techniques do not appear to be associated with any harms in adults, other than minor annoyances associated with mouth taping at night, but the evidence to support this is low.
- Yoga breathing techniques do not appear to be associated with any harms in adults, but the evidence to support this is low.
- There was no evidence on harms associated with IMT or other non-hyperventilation reduction approaches in adults or children.

Seven trials reported on adverse events,51,53,55,57,58,61,62 five of which examined a hyperventilation reduction approach compared with either a control or another breathing retraining approach,51,53,55,57,58 and two examined yoga interventions.61,62 Three of the seven studies (including one yoga trial62) noted that there were no adverse events or harms that occurred in either the intervention or control group over 16 to 52 weeks of intervention and followup.53,55,62 One study of a Buteyko breathing technique intervention, compared to a relaxation control group, noted that one hospitalization occurred with one member of the control group.57 Another study comparing a Buteyko breathing technique intervention delivered by video with a placebo intervention involving nonspecific upper body mobility exercises reported 138 adverse events in the Buteyko breathing technique group and 121 in placebo group, none of which was considered to be related to treatment.58 The trial of comprehensive naturopathic treatment reported mild headache, fatigue, and/or nausea, which they attributed to the use of the supplements and not yoga.61 In the study focused on the effect of a nighttime mouth-taping intervention, participants reported problems related to the intervention including it being uncomfortable, causing sore lips, making breathing more difficult, feeling unnatural, decreasing sleep quality, causing a feeling a suffocation, or was embarrassing.51

## Key Question 3a Do the safety or adverse effects of treatment with breathing techniques differ between different subgroups (e.g., adults/children; males/females; different races or ethnicities; smokers/nonsmokers; various types and severities of asthma; and/or different coexisting conditions)?

Key Points:

- There was no evidence on whether patient characteristics influenced the likelihood of experience harm in adults or children from any treatment included in the review.

No trials examined harms of treatment within subgroups or compared subgroups on likelihood of harms.