# References

1 National Asthma Education and Prevention Program. Expert Panel Report 3: Guidelines for the Diagnosis and Management of Asthma. Bethesda, MD. National Heart, Lung, and Blood Institute. 2007.
2 Akinbami LJ, Moorman JE, Liu X. Asthma Prevalence, Health Care Use, and Mortality: United States, 2005–2009, National Health Statistics Report. Hyattsville, MD. National Center for Health Statistics. 2011;32. [pmid: 21355352].
3 American Lung Association - Epidemiology and Statistics Unit Research and Program Services Division. Trends in Asthma Morbidity and Mortality. American Lung Association. Washinton, DC. American Lung Association. 2009.
4 Centers for Disease Control and Prevention. Current Asthma Prevalence Percents by Age, United States: National Health Interview Survey, 2007. 2008. www.cdc.gov/Asthma/nhis/07/table4-1.htm. Accessed May 18, 2010.
5 Vollmer WM, Markson LE, O’Connor E, et al. Association of asthma control with health care utilization: a prospective evaluation. Am J Respir Crit Care Med. Jan. 15. 2002;165(2):195-99. [pmid: 11790654].
6 Vollmer WM, Markson LE, O’Connor E, et al. Association of asthma control with health care utilization and quality of life. Am J Respir Crit Care Med. Nov. 1999;160(5 Pt 1):1647-52. [pmid: 10556135].
7 Panettieri RA Jr, Covar R, Grant E, et al. Natural history of asthma: persistence versus progression-does the beginning predict the end?. J Allergy Clin Immunol. Mar. 2008;121(3):607-13. [pmid: 18328890].
8 Martinez FD, Wright AL, Taussig LM, et al. Asthma and wheezing in the first six years of life. The Group Health Medical Associates. N Engl J Med. Jan. 19. 1995;332(3):133-38. [pmid: 7800004].
9 Illi S, von ME, Lau S, et al. Perennial allergen sensitisation early in life and chronic asthma in children: a birth cohort study. Lancet. Aug. 26. 2006;368(9537):763-70. [pmid: 16935687].
10 Vollmer WM, Heumann MA, Breen VR, et al. Incidence of work-related asthma in members of a health maintenance organization. J Occup Environ Med. Dec. 2005;47(12):1292-97. [pmid: 16340711].
11 Standardization of Spirometry, 1994 Update. American Thoracic Society. Am J Respir Crit Care Med. Sep. 1995;152(3):1107-36. [pmid: 7663792].
12 Williams LK, Pladevall M, Xi H, et al. Relationship between adherence to inhaled corticosteroids and poor outcomes among adults with asthma. J Allergy Clin Immunol. Dec. 2004;114(6):1288-93. [pmid: 15577825].
13 Apter AJ, Reisine ST, Affleck G, et al. Adherence with twice-daily dosing of inhaled steroids. Socioeconomic and health-belief differences. Am J Respir Crit Care Med. Jun. 1998;157(6 Pt 1):1810-17. [pmid: 9620910].
14 Partridge MR, Dockrell M, Smith NM. The use of complementary medicines by those with asthma. Respir Med. Apr. 2003;97(4):436-38. [pmid: 12693806].
15 Shaw A, Thompson EA, Sharp D. Complementary therapy use by patients and parents of children with asthma and the implications for NHS care: a qualitative study. BMC Health Serv Res. 2006;6:76. [pmid: 16776833].
16 Product information - QVAR^®^. 2008. www.accessdata.fda.gov/drugsatfda_docs/label/2008/020911s017lbl.pdf. Accessed December 2, 2010.
17 Highlights of Prescribing Information - PROAIR HFA. 2010. www.accessdata.fda.gov/drugsatfda_docs/label/2010/021457s021lbl.pdf. Accessed March 25, 2010.
18 Ernst E. Complementary therapies for asthma: what patients use. J Asthma. 1998;35(8):667-71. [pmid: 9860087].
19 Shenfield G, Lim E, Allen H. Survey of the use of complementary medicines and therapies in children with asthma. J Paediatr Child Health. Jun. 2002;38(3):252-57. [pmid: 12047692].
20 Shen J, Oraka E. Complementary and alternative medicine (CAM) use among children with current asthma. Prev Med. 2011. Oct. 15. [pmid: 22015560].
21 Stalmatski A. Freedom from asthma: Buteyko’s revolutionary treatment. London. Kyle Cathie Ltd. 1997.
22 British Thoracic Society, Scottish Intercollegiate Guideline Network. British guideline on the management of asthma, A national clinical guideline. Updated May 2011. Edinburgh, Scotland. Scottish Intercollegiate Guidelines Network. 2008:101.
23 Cluff RA. Chronic hyperventilation and its treatment by physiotherapy: discussion paper. J R Soc Med. Oct. 1984;77(10):855-62. [pmid: 6387113].
24 Holloway EA. The role of the physiotherapist in the treatment of hyperventilation. Timmon BH, Hornsveld H, Garssen B, editors. Behavioral and psychological approaches to breathing disorders. New York. Plenom Press. 1994.
25 Osborne CA, O’Connor BJ, Lewis A, et al. Hyperventilation and asymptomatic chronic asthma. Thorax. Dec. 2000;55(12):1016-22. [pmid: 11083886].
26 van den Elshout FJ, van Herwaarden CL, Folgering HT. Effects of hypercapnia and hypocapnia on respiratory resistance in normal and asthmatic subjects. Thorax. Jan. 1991;46(1):28-32. [pmid: 1908137].
27 Courtney R, Cohen M. Investigating the claims of Konstantin Buteyko, M.D., Ph.D.: the relationship of breath holding time to end tidal CO2 and other proposed measures of dysfunctional breathing. J Altern Complement Med. Mar. 2008;14(2):115-23. [pmid: 18315509].
28 Chandra FA. Respiratory practices in yoga. Timmons BH, Ley R, editors. Behavioral and Psychological Approaches to Breathing Disorders. New York. Springer. 1994:221-32.
29 Lehrer PM, Woolfolk RL. Respiratory system involvement in Western relaxation and self-regulation. Ley R, Timmons BH, editors. Behavioral and psychological approaches to breathing disorders. New York. Springer. 1994:191-203.
30 Lehrer P, Feldman J, Giardino N, et al. Psychological aspects of asthma. J Consult Clin Psychol. Jun. 2002;70(3):691-711. [pmid: 12090377].
31 Courtney R, Cohen M, van Dixhoorn J. Relationship between dysfunctional breathing patterns and ability to achieve target heart rate variability with features of “coherence” during biofeedback. Alt Ther Health Med. May. 2011;17(3):38-44. [pmid: 22164811].
32 Whitlock EP, Lopez S, Chang S, et al. AHRQ Series Paper 3: Identifying, selecting, and refining topics for comparative effectiveness systematic reviews. J Clin Epidemiol. 2010;63:491-501. [pmid: 19540721].
33 Fluge T, Richter J, Fabel H, et al. Long-term effects of breathing exercises and yoga in patients suffering from bronchial asthma. Pneumologie. 1994;48:484-90. [pmid: 7937658].
34 Rocha EM. The effect of respiratory rehabilitation on the functional ventilation changes in the asthmatic child. Allerg Immunol (Paris). 1993;25(1):26-28. [pmid: 8471136].
35 Official site about the Buteyko method. Voronezh, Russia. Voronezh Center. 2011. www.buteyko.ru/eng/method.shtml. Accessed December 15, 2011.
36 Buteyko Breathing Educators Association Inc. Clinical studies on Buteyko. Indianapolis, IN. Buteyko Breathing Educators Association, Inc. 2011. www.buteykoeducators.org/content.aspx?page_id=22&club_id=174916&module_id=76001. Accessed December 15, 2011.
37 Wolf F, Guevara JP, Grum CM, et al. Education interventions for asthma in children. Cochrane Database Syst Rev. 2008;(4). [pmid: 12535395].
38 Gibson PG, Powell H, Wilson A, et al. Limited (information only) patient education programs for adults with asthma. Cochrane Database Syst Rev. 2008;(1). [pmid: 12076400].
39 Welsh EJ, Hasan M, Li P. Home-based educational interventions for children with asthma. Cochrane Database Syst Rev. 2011;(10). [pmid: 21975783].
40 Gibson PG, Powell H, Wilson A, et al. Self-management education and regular practitioner review for adults with asthma. Cochrane Database Syst Rev. 2009;(3). [pmid: 12535399].
41 Coffman JM, Cabana MD, Yelin EH. Do school-based asthma education programs improve self-management and health outcomes?. Pediatrics. Aug. 2009;124(2):729-42. [pmid: 19651589].
42 Coffman JM, Cabana MD, Halpin HA, et al. Effects of asthma education on children’s use of acute care services: a meta-analysis. Pediatrics. Mar. 2008;121(3):575-86. [pmid: 18310208].
43 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
44 Cohen J. Statistical power analysis for the behavioral sciences. Hillsdale, NJ. Lawrence Erlbaum Associates, Inc. 1988.
45 Jones PW. Interpreting thresholds for a clinically significant change in health status in asthma and COPD. Eur Respir J. Mar. 2002;19(3):398-404. [pmid: 11936514].
46 Juniper EF, Guyatt GH, Cox FM, et al. Development and validation of the Mini Asthma Quality of Life Questionnaire. Eur Respir J. Jul. 1999;14(1):32-38. [pmid: 10489826].
47 Juniper EF, Guyatt GH, Epstein RS, et al. Evaluation of impairment of health related quality of life in asthma: development of a questionnaire for use in clinical trials. Thorax. Feb. 1992;47(2):76-83. [pmid: 1549827].
48 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
49 Atkins D, Chang S, Gartlehner G, et al. Assessing applicability when comparing medical interventions. J Clin Epidemiol. 2010. [pmid: 21463926].
50 Bowler SD, Green A, Mitchell CA. Buteyko breathing techniques in asthma: a blinded randomised controlled trial. Med J Aust. Dec. 7. 1998;169(11–12):575-78. [pmid: 9887897].
51 Cooper S, Oborne J, Harrison T, et al. Effect of mouth taping at night on asthma control--a randomised single-blind crossover study. Respir Med. Jun. 2009;103(6):813-19. [pmid: 19285849].
52 Cooper S, Oborne J, Newton S, et al. Effect of two breathing exercises (Buteyko and pranayama) in asthma: a randomised controlled trial. Thorax. Aug. 2003;58(8):674-79. [pmid: 12885982].
53 Cowie RL, Conley DP, Underwood MF, et al. A randomised controlled trial of the Buteyko technique as an adjunct to conventional management of asthma. Respir Med. May. 2008;102(5):726-32. [pmid: 18249107].
54 Grammatopoulou EP, Skordilis EK, Stavrou N, et al. The effect of physiotherapy-based breathing retraining on asthma control. J Asthma. Aug. 2011;48(6):593-601. [pmid: 21668321].
55 Holloway EA, West RJ. Integrated breathing and relaxation training (the Papworth method) for adults with asthma in primary care: a randomised controlled trial. Thorax. Dec. 2007;62(12):1039-42. [pmid: 17573445].
56 McGowan J. Health education in asthma management - does the Buteyko Institute method make a difference?. Thorax. 2003;58(Suppl 3):iii-28.
57 Opat AJ, Cohen MM, Bailey MJ, et al. A clinical trial of the Buteyko Breathing Technique in asthma as taught by a video. J Asthma. 2000;37(7):557-64. [pmid: 11059522].
58 Slader CA, Reddel HK, Spencer LM, et al. Double blind randomised controlled trial of two different breathing techniques in the management of asthma. Thorax. Aug. 2006;61(8):651-56. [pmid: 16517572].
59 Thomas M, McKinley RK, Mellor S, et al. Breathing exercises for asthma: a randomised controlled trial. Thorax. Jan. 2009;64(1):55-61. [pmid: 19052047].
60 Khare KC, Sanghvi VC, Bhatnagar AD, et al. Effect of Yoga in treatment of bronchial asthma. Indian Pract. 1991;44:23-27.
61 Kligler B, Homel P, Blank AE, et al. Randomized trial of the effect of an integrative medicine approach to the management of asthma in adults on disease-related quality of life and pulmonary function. Altern Ther Health Med. Jan. 2011;17(1):10-15. [pmid: 21614939].
62 Sabina AB, Williams AL, Wall HK, et al. Yoga intervention for adults with mild-to-moderate asthma: a pilot study. Ann Allergy Asthma Immunol. May. 2005;94(5):543-48. [pmid: 15945557].
63 Saxena T, Saxena M. The effect of various breathing exercises (pranayama) in patients with bronchial asthma of mild to moderate severity. Int J Yoga. Jan. 2009;2(1):22-25. [pmid: 21234211].
64 Vempati R, Bijlani RL, Deepak KK. The efficacy of a comprehensive lifestyle modification programme based on yoga in the management of bronchial asthma: a randomized controlled trial. BMC Pulm Med. 2009;9:37. [pmid: 19643002].
65 Lima EV, Lima WL, Nobre A, et al. Inspiratory muscle training and respiratory exercises in children with asthma. J Bras Pneumol. Aug. 2008;34(8):552-58. [pmid: 18797738].
66 Shaw BS, Shaw I. Static standing posture and pulmonary function in moderate-persistent asthmatics following aerobic and diaphragmatic breathing training. Pak J Med Sci. 2011;27(3):549-52.
67 Weiner P, Azgad Y, Ganam R, et al. Inspiratory muscle training in patients with bronchial asthma. J Asthma. Nov. 1992;102(5):1357-61. [pmid: 1424851].
68 Weiner P, Magadle R, Massarwa F, et al. Influence of gender and inspiratory muscle training on the perception of dyspnea in patients with asthma. J Asthma. Jul. 2002;122(1):197-201. [pmid: 12114358].
69 Weiner P, Berar-Yanay N, Davidovich A, et al. Specific inspiratory muscle training in patients with mild asthma with high consumption of inhaled beta(2)-agonists. J Asthma. Mar. 2000;117(3):722-27. [pmid: 10712997].
70 Lehrer PM, Vaschillo E, Vaschillo B, et al. Biofeedback treatment for asthma. J Asthma. Aug. 2004;126(2):352-61. [pmid: 15302717].
71 Thomas M, McKinley RK, Freeman E, et al. Breathing retraining for dysfunctional breathing in asthma: a randomised controlled trial. Thorax. Feb. 2003;58(2):110-15. [pmid: 12554890].
72 Breathing and relaxation exercises for adult patients diagnosed with asthma in primary care: a randomised controlled trial. Curr Control Trials. 2011.
73 Bowler S, Green A, Mitchell C, et al. Hypoventilation exercises buteyko breathing and asthma: a controlled trial. Aust N Z J Med. 1995;25:457.
74 Central Council for Research in Yoga & Naturopathy (CCRYN). Effect of yoga on pulmonary function, mast cell activation and quality of life in bronchial asthma: a randomised controlled trial. Curr Control Trials. 2010.
75 Cooper S, Oborne J, Newton S, et al. Do breathing exercises (buteyko and pranayama) help to control asthma: a randomised controlled trial. European Respiratory Society Annual Congress. 2002.
76 Lehrer PM, Vaschillo E, Vaschillo B, et al. A nondrug (biofeedback) treatment for asthma. Biol Psychol. 2004;67:409.
77 Opat A, Cohen M, Bailey M, et al. The Buteyko breathing techniques in asthma: a clinical trial. Proceedings of the Thoracic Society of Australia & New Zealand, Annual Scientific Meeting. Canberra. 1999:36.
78 Thomas M, McKinley RK, Proger P, et al. Breathing retraining improves for dysfunctional breathing in asthma. Biol Psychol. 2001;59:248. [pmid: 12554890].
79 Thomas M, McKinley R, Mellor R, et al. Are breathing exercises helpful in asthma?. Prim Care Respir J. 2008;17:121. [pmid: 19052047].
80 Thomas M, McKinley R, Mellor S, et al. Breathing training improves asthma symptoms but not airways inflammation or hyper-reactivity in asthma. European Respiratory Society Annual Congress. Berlin, Germany. 2008:3498.
81 Thomas M, McKinley R, Mellor S, et al. Breathing training exercises result in persistent improvements in asthma health status at 12 months. European Respiratory Society Annual Congress. Vienna, Austria. 2009:1379.
82 Thompson Coon J. Physiotherapy-based breathing retraining may improve the well-being of patients with asthma. Focus Alt Comp Ther. 2003;8(3):344-45.
83 Vempati R, Bijlani R. A controlled study on the efficacy of yoga in bronchial asthma. International Conference on Yoga and Its Applications. 2004. Melbourne. Australia. 2004.
84 Vempati R, Manjunatha R, Bijlani RL. A randomized controlled trial on the efficacy of yoga in the management of bronchial asthma. Indian J Physiol Pharmacol. 2004;48(5):242-43.
85 Vempati R, Bijlani RL, Deepak KK. Effect of yoga on exercise induced bronchoconstriction and urinary prostaglandin D2 metabolite in bronchial asthma. Allergy Clin Immunol Int. 2005;(1):593.
86 Vempati R, Deepak KK. Effect of yogic practices on airway inflammation, mast cell activation and exercise induced asthma: a randomized controlled trial. Allergy. 2007;62(Suppl 83):217.
87 Vempati R, Deepak KK. The use of Yoga as an adjuvant therapy in the management of bronchial asthma: based on a randomized controlled trial. World Allergy Congress. Bangkok, Thailand. 2007.
88 White AR. Positive evidence of the effectiveness of Buteyko breathing techniques in asthma. Focus Alt Comp Ther. Dec. 1999;4(4):207-08.
89 Ziment I, Cooper S. Breathing technique benefits asthma patients. Focus Alt Comp Ther. Mar. 2004;9(1):45-46.
90 Lehrer P, Vaschillo E, Lu SE, et al. Heart rate variability biofeedback: effects of age on heart rate variability, baroreflex gain, and asthma. Chest. Feb. 2006;129(2):278-84. [pmid: 16478842].
91 Shaw I, Shaw BS, Brown GA. Role of diaphragmatic breathing and aerobic exercise in improving pulmonary function and maximal oxygen consumption in asthmatics. Science and Sports. 2010;25(3):139-45.
92 Meuret AE, Ritz T, Wilhelm FH, et al. Targeting pCO(2) in asthma: pilot evaluation of a capnometry-assisted breathing training. Appl Psychophysiol Biofeedback. Jun. 2007;32(2):99-109. [pmid: 17564826].
93 Meuret AE, Ritz T, Wilhelm FH, et al. Pco2 Biofeedback-Assisted Breathing Training for Panic Disorder and Asthma: Rationale and Empirical Findings. 64th Annual Scientific Conference of the American Psychosomatic Society. 2006 Mar 1. Denver. American Psychosomatic Society. 2008.
94 Ritz T, Meuret AE, Wilhelm FH, et al. Changes in pCO2, symptoms, and lung function of asthma patients during capnometry-assisted breathing training. Appl Psychophysiol Biofeedback. Mar. 2009;34(1):1-6. [pmid: 19048369].
95 Vedanthan PK, Kesavalu LN, Murthy KC, et al. Clinical study of yoga techniques in university students with asthma: a controlled study. Allergy Asthma Proc. Jan. 1998;19(1):3-9. [pmid: 9532318].
96 Nathan RA, Sorkness CA, Kosinski M, et al. Development of the asthma control test: a survey for assessing asthma control. J Allergy Clin Immunol. Jan. 2004;113(1):59-65. [pmid: 14713908].
97 Schatz M, Sorkness CA, Li JT, et al. Asthma Control Test: reliability, validity, and responsiveness in patients not previously followed by asthma specialists. J Allergy Clin Immunol. Mar. 2006;117(3):549-56. [pmid: 16522452].
98 Juniper EF, Svensson K, Mork AC, et al. Measurement properties and interpretation of three shortened versions of the asthma control questionnaire. Respir Med. May. 2005;99(5):553-58. [pmid: 15823451].
99 McGowan J. Email communication. O’Connor E. August. 11. 2011.
100 Juniper EF, O’Byrne PM, Guyatt GH, et al. Development and validation of a questionnaire to measure asthma control. Eur Respir J. Oct. 1999;14(4):902-07. [pmid: 10573240].
101 Juniper EF, O’Byrne PM, Ferrie PJ, et al. Measuring asthma control. Clinic questionnaire or daily diary?. Am J Respir Crit Care Med. Oct. 2000;162(4 Pt 1):1330-34. [pmid: 11029340].
102 Jones PW, Quirk FH, Baveystock CM. The St George’s Respiratory Questionnaire. Respir Med. Sep. Suppl B. 1991;85:25-31. [pmid: 1759018].
103 Marks GB, Dunn SM, Woolcock AJ. A scale for the measurement of quality of life in adults with asthma. J Clin Epidemiol. May. 1992;45(5):461-72. [pmid: 1588352].
104 van Dixhoorn J, Duivenvoorden HJ. Efficacy of Nijmegen Questionnaire in recognition of the hyperventilation syndrome. J Psychosom Res. 1985;29(2):199-206. [pmid: 4009520].
105 Ware JE Jr, Sherbourne CD. The MOS 36-item short-form health survey (SF-36). I. Conceptual framework and item selection. Med Care. Jun. 1992;30(6):473-83. [pmid: 1593914].
106 Zigmond AS, Snaith RP. The hospital anxiety and depression scale. Acta Psychiatr Scand. Jun. 1983;67(6):361-70. [pmid: 6880820].
107 Pereira TV, Ioannidis JP. Statistically significant meta-analyses of clinical trials have modest credibility and inflated effects. J Clin Epidemiol. Oct. 2011;64(10):1060-69. [pmid: 21454050].
108 Herbison P, Hay-Smith J, Gillespie WJ. Meta-analyses of small numbers of trials often agree with longer-term results. J Clin Epidemiol. Feb. 2011;64(2):145-53. [pmid: 20609563].
109 Buteyko a..z. Russia: Russian Buteyko Breathing Technique. 2006. www.buteyko.com/research/trials/index_trials.html. Accessed September 7, 2011.
110 James T. Doctors gasp at Buteyko success. Instep Asthma Free. 1995. www.nqnet.com/buteyko/Asthma_relief_pressd.html. Accessed September 7, 2011.
111 O’Connell P. Buteyko - UK Clinical Trial 6 of 17. Australia. YouTube. 2008. www.youtube.com/watch?v=DhIRx3ugwgI&feature=related. Accessed September 7, 2011.
112 McHugh P, Aitcheson F, Duncan B, et al. Buteyko Breathing Technique for asthma: an effective intervention. N Z Med J. Dec. 12. 2003;116(1187):U710. [pmid: 14752538].
113 Sodhi C, Singh S, Dandona PK. A study of the effect of yoga training on pulmonary functions in patients with bronchial asthma. Indian J Physiol Pharmacol. Apr. 2009;53(2):169-74. [pmid: 20112821].
114 Manocha R, Marks GB, Kenchington P, et al. Sahaja yoga in the management of moderate to severe asthma: a randomised controlled trial. Thorax. Feb. 2002;57(2):110-15. [pmid: 11828038].
115 Nagarathna R, Nagendra HR. Yoga for bronchial asthma: a controlled study. Br Med J (Clin Res Ed). Oct. 19. 1985;291(6502):1077-79. [pmid: 3931802].
116 McCall TB. Western Science vs. Eastern Wisdom Yoga Journal. Jan. 2003;(172):88.
117 Weiner P, Magadle R, Beckerman M, et al. The relationship among inspiratory muscle strength, the perception of dyspnea and inhaled beta2-agonist use in patients with asthma. Can Respir J. Sep. 2002;9(5):307-12. [pmid: 12410322].
118 Ram FSF, Wellington SR, Barnes NC, et al. Inspiratory muscle training for asthma. Cochrane Database Syst Rev. Article Number CD003792. 2009;4.
119 Wechsler ME, Kelley JM, Boyd IO, et al. Active albuterol or placebo, sham acupuncture, or no intervention in asthma. N Engl J Med. Jul. 14. 2011;365(2):119-26. [pmid: 21751905].
120 Lehrer PM, Karavidas MK, Lu SE, et al. Psychological treatment of comorbid asthma and panic disorder: a pilot study. J Anxiety Disord. May. 2008;22(4):671-83. [pmid: 17693054].
121 Sato K, Kawamura T, Abo T. “Senobi” stretch ameliorates asthma symptoms by restoring autonomic nervous system balance. J Investig Med. Dec. 2010;58(8):968-70. [pmid: 20930645].
122 Breathing Center. Practitioners. Woodstock, NY. Buteyko Center USA. 2009. www.breathingcenter.com/practitioners.html. Accessed December 30, 2011.
123 Butyeko Institute of Breathing and Health. Find a BIBH practitioner. Australia. Butyeko Institute of Breathing and Health. 2011. www.buteyko.info/find_a_buteyko_practitioner.asp. Accessed December 30, 2011.
124 Buteyko Breathing Educators Association Inc. Find a Buteyko educator. Indianapolis, IN. Buteyko Breathing Educators Association, Inc. 2011. www.buteykoeducators.org/content.aspx?page_id=78&club_id=174916. Accessed December 30, 2011.
125 Buteyko VK, Buteyko MM. The Buteyko theory about a key role of breathing for human health. Voronezh, Russia. Butyeko Co, Ltd. 2005.
126 Moher D, Pham B, Lawson ML, et al. The inclusion of reports of randomised trials published in languages other than English in systematic reviews. Health Technol Assess. 2003;7(41):1-90. [pmid: 14670218].
127 Anokhin MI, Sergeev VN, Domanskii VL. Biological feedback correction of respiration during treatment of bronchial asthma. Biomed Eng (NY). 1996;30(1):26-29.
128 Girodo M, Ekstrand KA, Metivier GJ. Deep diaphragmatic breathing: rehabilitation exercises for the asthmatic patient. Arch Phys Med Rehabil. Aug. 1992;73(8):717-20. [pmid: 1642520].
129 Bingol Karakoc G, Yilmaz M, Sur S, et al. The effects of daily pulmonary rehabilitation program at home on childhood asthma. Allergol Immunopathol (Madr). Jan. 2000;28(1):12-14. [pmid: 10757852].
130 Lehrer P, Carr RE, Smetankine A, et al. Respiratory sinus arrhythmia versus neck/trapezius EMG and incentive inspirometry biofeedback for asthma: a pilot study. Applied Psychophysiol Biofeedback. Jun. 1997;22(2):95-109. [pmid: 9341966].
131 Abramson M, Borg B, Doran C, et al. A randomised controlled trial of the Buteyko method for asthma. Int J Immunorehabil. 2004;6(2):244. [pmid: 11059522].
132 Breathing training leads to improved asthma-specific health status. AJP. 2010;91(1076):62-63.
133 Bhikshapathi DVRN, Jayanthi C, Kishan V, et al. Influence of yogasanas on the physiology, therapy and theophylline pharmacokinetics in bronchial asthma patients. Acta Pharm Sci. 2007;49(2):187-94.
134 Cooper SE, Oborne J, Newton S, et al. The effect of two breathing exercises (Buteyko and Pranayama) on the ability to reduce inhaled corticosteroids in asthma: a randomised controlled trial. American Thoracic Society 99th International Conference. 2003:B023.
135 Cowie RL, Conley DP, Underwood MF, et al. A randomized controlled trial of buteyko technique for asthma management. Proceedings of the American Thoracic Society. American Thoracic Society International Conference. 2006 May 19. San Diego, CA. 2006:A530.
136 Neffen HE, Baena-Cagnani CE, Yanez A. Breathing Exercises for Asthmatic Children: Asthma Music and the Asthma Symphony. 16th World Congress of Asthma. Buenos Aires, Argentina. 1999:83-88.
137 Vijayaraghayan N. Role of yoga in the management of bronchial asthma. 6th World Congress on Holistic Life and Medicine. Calicut, India. 1996:137-40.
138 Yorke J, Fleming SL, Shuldham C. Psychological interventions for adults with asthma. Cochrane Database Syst Rev. 2009;(1):i-63. [pmid: 16235317].
139 Bruton A, Garrod R, Thomas M. Respiratory physiotherapy: towards a clearer definition of terminology. Physiotherapy. 2011;97(4):345-49. [pmid: 22051592].