# Methods

The Agency for Healthcare Research and Quality (AHRQ) requested a Comparative Effectiveness Review on the effectiveness of breathing exercises and/or retraining for the treatment of asthma as part of its Effective Health Care (EHC) program. The Oregon Evidence-based Practice Center (EPC) established a team and a protocol to develop the evidence report.

## Topic Development and Refinement

The topic for this report was nominated through a public process. The Scientific Resource Center (SRC) for the AHRQ Effective Health Care Program compiled information about this topic to evaluate its priority for a comparative effectiveness review. This information was evaluated and discussed by staff of the EHC and was approved for a full review.32

The Oregon EPC drafted a topic refinement document with proposed Key Questions after consulting with seven Key Informants. Key Informants included Western allopathic and alternative medical providers and representatives of patient advocacy groups. The alternative medical practitioners covered the areas of Buteyko breathing technique, yoga breathing techniques, and the Papworth breathing retraining method.

The Key Questions were posted on AHRQ’s website for public comment in August and September of 2010 for 4 weeks and were revised as needed. We then drafted a protocol for the comparative effectiveness review and recruited a technical expert panel (TEP) to provide high-level content and methodological expertise throughout the review. The TEP was comprised of five individuals who specialize in asthma management from the fields of family medicine, community health and nursing, psychology, physical therapy, and pediatrics. The TEP was set up to ensure the scientific rigor, reliability, and methodological soundness of the research. The TEP provided comments on the methods protocol and provided input on substantive issues such as typical use of asthma medication, clinical value of outcomes, and clinical importance of effect sizes.

## Analytic Framework

The analytic framework for evaluating the comparative effectiveness of breathing exercises and/or retraining for the treatment of asthma is shown in Figure 1. In general, the figure illustrates how the use of breathing exercises or retraining may result in intermediate outcomes (e.g., FEV_1_ or PEF, and/or ultimate health outcomes (e.g., reduced symptom severity and improved quality of life). The figure also depicts the possibility of adverse events occurring after treatment. We did not systematically review the association between pulmonary function test results and asthma symptoms, along with other health outcomes.

Figure 1 Analytic framework

FEV_1_: forced expiratory volume in 1 second; FVC: forced vital capacity; MV: minute volume; PEF: peak expiratory flow

Figure 1 is an analytic framework that depicts the key questions described in the methods section of the report. In general, the figure illustrates how the use of breathing exercises or retraining techniques may result in improved intermediate outcomes such as forced expiratory volume or peak expiratory flow, and/or improved heath outcomes such as improved symptom severity and quality of life. The figure also depicts the possibility of adverse events occurring after treatment.

## Literature Search Strategy

A research librarian performed comprehensive literature searches in the following databases:

- MEDLINE accessed via PubMed
- PsycInfo
- EMBASE
- Cumulative Index to Nursing and Allied Health Literature (CINAHL)
- Physiotherapy Evidence Database (PEDro)
- Cochrane Central Register of Controlled Trials (CCRCT)
- AltHealthWatch
- Allied and Complementary Medicine (AMED)
- Manual, Alternative and Natural Therapy Index System (MANTIS)
- Indian Medical Journals (IndMED)

Appendix B outlines our search strategy for each database. These searches were used to locate relevant studies related to all three Key Questions. Searches were restricted to the time period of 1990 to December 8, 2011. While we did not have translation services available to review non-English papers, we were able to find English-language abstracts or use electronic translation tools on non-English abstracts for all non-English articles that may have met inclusion criteria, based on the title of the article. Only two trials possibly appeared to meet our inclusion/exclusion criteria, based on the abstracts, but were not reviewed further because we did not have translation services available.33,34 Titles and abstracts of these studies are presented in Appendix C.

In addition, because the Buteyko methods were developed in Russia, there may be relevant early research published only in Russian and not included on the databases we searched. Therefore, we searched Buteyko websites for reference to non-English studies that might meet our inclusion criteria.35,36 One website listed 73 publications by Buteyko himself or his collaborators in Russian, and while it is possible that there was a trial listed among then, none included the word “trial” in the title and all appeared to be studies of pathophysiology, case series, or instructions in the use of the Buteyko method.35

Searches of these databases were supplemented with manual searching of reference lists contained in all included articles and in relevant review articles. We specifically examined reviews of asthma education programs for trials with any mention of breathing techniques for asthma management published during our search window (1990 to present).37–42 Grey literature searches were also performed by the research librarian. For the purposes of this review, grey literature refers to any information that is not controlled by commercial publishing and included regulatory documents (e.g., U.S. Food and Drug Administration Medical and Statistical Reviews and Authorized Medicines for the European Union); clinical trial registry entries (e.g., ClinicalTrials.gov, the World Health Organization International Trials Registry Platform, and Current Controlled Trials Register); and conference abstracts (e.g., CSA’s Conference Papers Index, Scopus conference papers, ProceedingsFirst, and PapersFirst). Upon receipt of the grey literature search results, we reviewed abstracts and/or full-text results according to the methods described below. We matched abstracts to any published studies and reviewed them in conjunction with the full text of these studies. In addition, a Scientific Information Packet (SIP) was requested from one relevant organization that produces materials and educational training for one intervention of relevance to this review (Buteyko Institute of Breathing and Health, Manuka, Australia). However, we did not receive a SIP.

The results of our searches were downloaded and imported into version 11.0.1 of Reference Manager^®^ (Thomson Reuters, New York, NY), a bibliographic management database. We manually scanned for duplicates. Reference Manager was used to track the search results at the levels of title/abstract review and article inclusion/exclusion.

## Process for Study Selection

A two-step process was used for study selection. First, two members of the research team independently reviewed each title and abstract (if available) to determine if an article met the broad inclusion/exclusion criteria for study design, population, and intervention (Table 1). Each title/abstract was coded as: potentially included, excluded, or background. Next, we retrieved full-text articles for all potentially included studies, including those that were questionable or unclear at the abstract stage. Two reviewers independently assessed each full-text article using a standard form that detailed the predetermined inclusion and exclusion criteria. Disagreements were resolved through discussion.

Table 1 Inclusion and exclusion criteria

Category | Inclusion Criteria | Exclusion Criteria
Population | - Humans, all races, ethnicities, cultural groups; - Adults aged ≥ 18 years with asthma of any type and severity, symptomatic or using asthma medication; - Children ≥ 5 years with asthma of any type and severity, symptomatic or using asthma medication; - Asthma diagnosis by medical practitioner (self-report of physician diagnosis acceptable) | - Children < 5 years; - Individuals with comorbid chronic obstructive pulmonary disease, emphysema, chronic bronchitis or any other chronic disease that affects pulmonary function (e.g., heart disease, thyroid disease)
Interventions | Interventions in which breathing retraining/exercises are a primary component. Such exercises include:; - Buteyko breathing technique (including those focused only on mouth taping; - Inspiratory muscle training; - Expiratory muscle training; - Diaphragmatic breathing techniques; - Breathing physical therapy (e.g., paced and pursed lip breathing exercises); - Papworth method; - Biofeedback- and other technology-assisted breathing retraining; - Yoga breathing exercises; - Other breathing exercises | - Interventions that do not focus primarily on asthma; - Interventions whereby breathing techniques are not a primary treatment; - In-hospital management of acute exacerbations; - Physical fitness training; - Alexander Technique
Comparator | - Other breathing techniques alone or in combination with other intervention strategies; - Usual care as standard for the setting (e.g., asthma self-management education, control of environmental factors, pharmacologic therapy); - Technology-supported placebo device; - Attention controls (receiving similar time and attention as the intervention group on another topic unrelated to breathing retraining); - Wait-list controls; - No treatment offered (outside care is assumed) | - Other alternative or complementary methods that are potentially efficacious for asthma and are not focused on breathing retraining [e.g., relaxation techniques (e.g., progressive muscle relaxation), acupuncture, herbal therapies, chiropractic]; - Physical activity or exercise
Outcomes | Key Question 1:; - Symptoms (e.g., cough, wheezing, dyspnea, nocturnal symptoms); - Health-related quality of life (general and/or asthma-specific); - Asthma control (e.g., acute exacerbations, hospitalizations for asthma, urgent or emergent clinic or hospital visits for asthma (including unscheduled doctor visits), nocturnal control, missed school/work, daily activity tolerance or restrictions); - Exercise tolerance (e.g., 6-minute walk, shuttle run); - Quick-relief medication use (e.g., short-acting beta_2_-agonists, anticholinergics); - Long-term control medications (e.g., inhaled corticosteroids, long-acting immunomodulators); Key Question 2:; - Pulmonary function tests: FEV_1_ % predicted; FVC % predicted; PEF; MV, exhaled nitric oxide, methylcholine challenge and/or responsiveness, sputum eosinophil markers of inflammation, other measures of CO_2_, other spirometry measures; Key Question 3:; - Increased asthma symptoms or acute asthma exacerbations; - Adverse reactions to therapies; - Reduction in/negative influences on quality of life | - Costs; - During or post-exercise breathlessness or pulmonary function (considered too highly correlated with fitness)
Time period | 1990 to present | Before 1990
Setting | All settings | Not applicable
Study geography | All locations
Publication language | English | All other languages
Study design | Key Questions 1, 2 and 3:; - Randomized controlled trials; - Controlled clinical trials; - Comparative observational studies (prospective and retrospective cohort studies; case-control studies); including only those controlling for medication use and health care use with long-term (≥ 6 month) outcomes, with some validity of case ascertainment or in those with broadly representative samples; Key Questions 1a and 2a:; - Randomized controlled trials; - Controlled clinical trials; - Comparative observational studies (prospective and retrospective cohort studies; case-control studies); including cohort of patients who have undergone breathing retraining, reliably divided into subgroups of interest, adequately powered to detect differences in outcomes between groups, and adequately controlling for confounders; Key Questions 1b and 2b:; - Randomized controlled trials; - Controlled clinical trials | Key Questions 1, 2 and 3:; - Editorials, letters, nonsystematic literature reviews; - Noncomparative observational studies (e.g., case-series, case reports, cross-sectional studies); - Comparative observations trials not meeting all inclusion criteria; Key Questions 1a and 2a:; - Editorials, letters, nonsystematic literature reviews; - Noncomparative observational studies (e.g., case-series, case reports, cross-sectional studies); - Comparative observations trials not meeting all inclusion criteria; Key Questions 1b and 2b:; - Editorials, letters, nonsystematic literature reviews; - Observational studies
Intervention duration | All | Not applicable
Follow-up duration | ≥ 4 weeks post intervention | < 4 weeks post intervention
Sample size | N ≥ 10 | N < 10

CO_2_: carbon dioxide; FEV_1_: forced expiratory flow in 1 second; FVC: forced vital capacity; MV: minute volume; PEF: peak expiratory flow

## Data Abstraction and Data Management

We abstracted data from all included studies with a quality rating of “fair” or “good” (see section below on individual study quality assessment) into a standard evidence table. One investigator abstracted the data and a second checked the data. Discrepancies regarding data abstraction were resolved by re-review, discussion, and comments from others. The following information was obtained from each study, where available: author identification; year of publication; study location; study design; recruitment setting and approach; inclusion/exclusion criteria; demographic and health characteristics of the sample including baseline asthma; description of the intervention and control arms; any co-intervention components (e.g., advise about diet, relaxation training); compliance with treatment; and sample retention. Outcomes included: asthma symptoms; medication and health care use; quality of life and functioning; pulmonary function; and adverse outcomes. We also recorded the instruments used to measure each outcome, where available. We contacted authors of included studies if clarification of methods (e.g., randomization methods) or results (e.g., providing missing data or verifying the data) was needed.

## Individual Study Quality Assessment

We used predefined criteria developed by the U.S. Preventive Services Task Force to assess the methodological quality of included studies.43 Two independent reviewers assigned a quality rating of the internal validity for each study. Disagreements were resolved by discussion and consensus. A rating of “good,” “fair,” or “poor” was assigned using the predefined criteria for studies meeting inclusion criteria. For randomized controlled trials (RCTs), specific areas assessed included:

- The presence of adequate randomization methods (use of computer-generated random number tables or other process considered truly random);
- Allocation concealment;
- Similarity of groups at baseline;
- The specification of eligibility criteria;
- Reliable and valid diagnosis or asthma (optimal assessment included use of pulmonary function testing to confirm reversible component);
- Retention (retention of 90% or more overall was considered good; 60 to 89% was adequate, and less than 60% was considered a fatal flaw; differential attrition of 10 to 19 percentage points was considered potentially problematic and 20 percentage points or more was considered a fatal flaw);
- Time to followup (6 months or more was preferable, fewer than 6 weeks was potentially problematic)
- Equal, reliable and valid measurements;
- Blinding of outcome assessors; and
- Appropriate analyses (e.g., analyzing all participants in the treatment group to which they were initially assigned, use of conservative data substitution [preferably multiple imputation, imputation based random effects regression or similar models, or use of baseline values] when retention was below 90%, adjustment for potential confounders, no use of statistical tests that were inappropriate for the type of data analyzed).

All of these items were used to evaluate the risk of bias. Generally, a good-quality study met all major criteria, though it was possible to get a “good” rating if an item was not reported (so could not be assessed) if the rest of the methods were judged to be “good.” A fair-quality study did not meet all criteria, but was judged to have no flaw so serious that it invalidated its results. A poor-quality study contained a serious flaw in design, analysis, or execution, such as differential attrition as described above, or some other flaw judged to be so serious as to cast doubt on the validity of the results. Examples of serious flaws include very large baseline group differences that were not or could not be adjusted for in an analysis, no information about followup and assumption of 100 percent followup was not tenable, or insufficient information was provided to determine the risk of bias.

We did not include studies rated as poor-quality in this review.

## Data Synthesis

We summarized all included studies in narrative form as well as in summary tables that present the important features of the study populations, design, intervention, outcomes, and results. We divided comparisons into five groups based on the primary intervention focus and control group: (1) interventions focused on hyperventilation reduction breathing training versus control, (2) yoga breathing methods versus control, (3) IMT versus control, (4) breathing approaches that did not focus on hyperventilation reduction versus control, and (5) hyperventilation reduction versus nonhyperventilation reduction breathing training approaches. Outcomes are discussed separately for each of the five groups.

To facilitate comparison of effect sizes across studies reporting different outcomes, when possible we calculated a standardized effect size (Hedges g) for group differences in change from baseline using Stata 11.2^®^ (Stata Corp, College Station, TX), where sufficient data were available for calculation. In calculating standardized effect sizes for asthma symptom outcomes, all scores were coded so that a higher score indicated more symptoms (worse outcome). For quality of life measures, all scores were coded so that a higher score indicated higher quality of life (better outcome). Random effects meta-analyses were conducted where there were at least three trials within a group. Meta-analyses were always conducted within groups because of the high degree of clinical and methodological heterogeneity across group. Statistical heterogeneity was evaluated using the I^2^ statistic. When trials reported multiple followup assessment, we pooled data from the assessment that was closest to the followup time reported by the other trials in the analysis to maximize consistency between studies. For trials with more than one control arm, we included the control group most similar in intensity to the intervention group that was included in the meta-analysis, thus choosing intensity-matched comparators wherever possible. We did not perform funnel plots or Egger’s test of small study effects to assess for publication bias because of the small number of trials included in each meta-analysis.

We used effect size as one method to judge the importance of an effect. Effect sizes larger than 0.80 were considered large effects.44 In addition, commonly used asthma scales have been examined to determine thresholds for clinically significant change in health status.45 A change of 0.05 has been suggested for the Juniper Asthma Quality of Life Questionnaires (AQLQ).46,47 For the St. George’s Respiratory Questionnaire (SGRQ), the threshold for clinical significance is estimated to be 4 units, and patients whose treatment was judged to have been “very effective” showed an average change of 8.1 units.45

In a separate exploratory qualitative analysis for Key Questions 1b and 2b, we stratified all trials (regardless of group) by a series of study characteristics of interest and examined the proportion of trials reporting positive results in trials with and without the pertinent characteristic. Characteristics examined included study quality rating (substantial quality concerns vs. average quality concerns), whether the comparator included a breathing or relaxation component, whether the intervention involved the use of a device, and whether the two groups being compared involved the same number of hours of contact and homework. We examined outcomes, including: asthma symptoms, reliever medication use, quality of life, and pulmonary function.

## Grading the Strength of Evidence

We graded the strength of evidence for primary outcomes using the standard process of the EPCs as outlined in the Methods Guide for Effectiveness and Comparative Effectiveness Reviews.48 Specifically, we assessed the strength of evidence for the major outcomes in each of the Key Questions. These outcomes included: (1) asthma symptoms and control, (2) asthma medication use, (3) quality of life and function for Key Question 1; and (4) pulmonary function test results for Key Question 2. The grade of evidence was based on four major domains: (1) risk of bias (low, medium, high), (2) consistency (no inconsistency present, inconsistency present, unknown or not applicable), (3) directness (direct, indirect), and (4) precision (precise, imprecise). Risk of bias is the degree to which the included studies for a given outcome or comparison has a high likelihood of adequate protection against bias. We evaluated risk of bias considering both study design and aggregate quality of the studies. Consistency refers to the degree to which reported effect sizes from included studies appear to have the same direction and magnitude of effect. We assessed the sign of the effect sizes (i.e., effects have the same direction) and whether the range of effect sizes was narrow. When only a single study was included, consistency could not be judged. Directness relates to whether the evidence links the interventions directly to health outcomes. For a comparison of two treatments, directness implies that head-to-head trials measure the most important outcomes. Precision refers to the degree of certainty surrounding an effect estimate with respect to a given outcome.

We assigned an overall strength of evidence grade based on the total number of studies addressing the outcome and the ratings for these four individual domains for each key outcome, and for each comparison of interest. The overall strength of evidence was rated using four basic grades (as described in the AHRQ Methods Guide): high, moderate, low, and insufficient (Table 2).48 We rated the evidence as insufficient when no studies were available for an outcome or comparison of interest, or the evidence is limited to small trials that are methodologically flawed and/or highly heterogeneous. Ratings were assigned based on our judgment of the likelihood that the evidence reflected the true effect for the major comparisons of interest.

Table 2 Strength of evidence grades and definitions

Grade | Definition
High | High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
Moderate | Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change the confidence in the estimate of effect and is likely to change the estimate.
Insufficient | Evidence is unavailable or does not permit a conclusion

## Applicability

To assess applicability, we used data abstracted on the population studied, the intervention and comparator, the outcomes measured, settings (including cultural context), and timing of assessments to identify specific issues that may limit the applicability of individual studies or the body of evidence to U.S. health care settings, as recommended in the Methods Guide.49 We used these data to evaluate applicability, paying special attention to study eligibility criteria, recruitment strategies, baseline demographic features (e.g., age, smoking status, and comorbid conditions) and the intervention characteristics (whether there were multiple interventionists, level/degree of training among interventionists, whether there was a clearly defined protocol).

## Review Process

A full draft report was reviewed by experts and posted for public commentary from November 9, 2011, through December 5, 2011. Comments received from either invited reviewers or through the public comment website were compiled and addressed. A disposition of comments will be posted on the Effective Healthcare Program Web site 3 months after the release of the evidence report.