# Peer Reviewers

Peer Reviewers are invited to provide written comments on the draft report based on their clinical, content, or methodologic expertise. Peer review comments on the preliminary draft of the report are considered by the EPC in preparation of the final draft of the report. Peer Reviewers do not participant in the writing or editing of the final report or other products. The synthesis of the scientific literature presented in the final report does not necessarily represent the views of individual reviewers. The dispositions of the peer review comments are documented and will, for CERs and Technical Briefs, be published 3 months after the publication of the Evidence Report.

Potential Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Invited Peer Reviewers may not have any financial conflicts of interest greater than $10,000. Peer Reviewers who disclose potential business or professional conflicts of interest may submit comments on draft reports through the public comment mechanism.

Adam Burke, Ph.D., M.P.H.

Director, Institute for Holistic Health Studies

Associate Professor, Department of Health Education

San Francisco State University

San Francisco, CA

Sian Cotton, Ph.D.

Assistant Professor, Department of Family and Community Medicine

University of Cincinnati

Cincinnati, OH

John D. Mark, M.D.

Pediatric Pulmonologist

Packard Children’s Hospital at Stanford

Palo Alto, CA

Mike Thomas, M.D.

Chief Medical Officer, Department of General Practice and Primary Care

University of Aberdeen

Aberdeen, United Kingdom