# Technical Expert Panel

Technical Experts comprise a multidisciplinary group of clinical, content, and methodologic experts who provide input in defining populations, interventions, comparisons, or outcomes as well as identifying particular studies or databases to search. They are selected to provide broad expertise and perspective specific to the topic under development. Divergent and conflicted opinions are common and perceived as health scientific discourse that results in thoughtful, relevant systematic review. Therefore, study questions, design, and/or methodological approaches do not necessary represent the views of the individual technical or content experts. Technical Experts provide information to the EPC to identify literature search strategies and recommend approaches to specific issues as requested by the EPC. Technical Experts do not do analysis of any kind, do not contribute to the writing of the report, and have not reviewed the report, except as given the opportunity to do so through the public review mechanism.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical and content expertise, individuals are invited to serve as Technical Experts, and those who present with potential conflicts may be retained. The Task Order Officer and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

Meg Hayes, M.D.

Associate Professor, Department of Family Medicine

Oregon Health and Science University

Portland, OR

Susan Janson, D.N.Sc., R.N., A.N.P., C.N.S., A.E-C., FAAN

Professor, Department of Community Health Systems

University of California, San Francisco, School of Nursing

San Francisco, CA

Alicia Meuret, Ph.D.

Assistant Professor, Department of Psychology

Southern Methodist University

Dallas, TX

Anne Swisher, P.T., Ph.D., C.C.S.

Associate Professor, Division of Physical Therapy

West Virginia University

Morgantown, WV

Robert Zeiger, M.D., Ph.D.

Clinical Professor, Department of Pediatrics

University of California, San Diego

Kaiser Permanente Medical Center

San Diego, CA