# Key Informants

Key Informants are the end users of research, including patients and caregivers, practicing clinicians, relevant professional and consumer organizations, purchasers of health care, and others with experience in making health care decisions. Within the EPC program, the Key Informant role is to provide input into identifying the Key Questions for research that will inform healthcare decisions. The EPC solicits input from Key Informants when developing questions for a systematic review or when identifying high-priority research gaps and future research needs. Key Informants are not involved in analyzing the evidence or writing the report and have not reviewed the report, except as given the opportunity to do so through the public review mechanism.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end users, individuals are invited to serve as Key Informants, and those who present with potential conflicts may be retained. The Task Order Officer and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

Chris Coniaris, R.Ph., CSPI

Certified Yoga Instructor

Amrita Sanctuary for Yoga

Portland, OR

Susanna Czeranko, N.D.

Licensed Naturopathic Physician and Instructor

National College of Natural Medicine

Portland, OR

Sandra Fusco-Walker

Director, Patient Advocacy

Allergy and Asthma Network Mothers of Asthmatics

Fairfax, VA

Elizabeth Holloway, Ph.D.

Chartered Physiotherapist, Department of Epidemiology and Public Health

University College London

London, England

David Jacoby, M.D., Ph.D.

Chief, Division of Pulmonary and Critical Care Medicine

Oregon Health and Science University

Portland, OR

Sarahjoy Marsh, M.A.

Certified Yoga Instructor

The Sanctuary, A Center for Yoga, Dharma, and Health Arts

Portland, OR

Nancy Sandler

President, Allergy and Asthma Network

Mothers of Asthmatics

Fairfax, VA