# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Daphne Plaut, M.L.S., Kevin Lutz, M.F.A., Christopher S. Peterson, and Sabrina Kosok, M.P.H.. In addition, we would like to thank all individuals who provided comments on our report.