# List of Excluded Studies

1 Abramson M, Borg B, Doran C, et al. A randomised controlled trial of the Buteyko method for asthma. Int J Immunorehabil. 2004;6(2):244. Abstract only, insufficient data to evaluate inclusion. [pmid: 11059522].
2 Agent P. Breathing training improves subjective health status but not pathophysiology in asthmatic adults. J Physiother. 2010;56(1):60. Synopsis of a potentially relevant study. [pmid: 20500141].
3 Anokhin MI, Sergeev VN, Domanskii VL. Biological feedback correction of respiration during treatment of bronchial asthma. Biomed Eng (NY). 1996;30(1):26-29. Other quality issues.
4 Breathing exercises help cut asthma symptoms. Practice Nurse. Jul. 13. 2007;34(1):8. Synopsis of a potentially relevant study.
5 Breathing training leads to improved asthma-specific health status. AJP. 2010;91(1076):62-63. Unable to obtain, unlikely a trial.
6 Inconclusive study of yoga as an adjunct therapy for asthma. 5th Annual Symposium Complementary Health Care. Exeter. 1998:164. Synopsis of a potentially relevant study.
7 Randomised controlled trial of treating dysfunctional breathing to reduce breathlessness in severe asthma. Curr Control Trials. 2011. Ongoing trial, no outcomes at time of review.
8 Asher MI, Douglas C, Airy M, et al. Effects of chest physical therapy on lung function in children recovering from acute severe asthma. Pediatr Pulmonol. 1990;9(3):146-51. Management of serious acute exacerbations. [pmid: 2277735].
9 Austin G, Brown C, Watson T, et al. Buteyko breathing technique improves exercise capacity and control of breathing in uncontrolled asthma. European Respiratory Society Annual Congress. Vienna, Austria. 2009:E4306. Not a study of breathing techniques.
10 Austin G, Brown C, Watson T, et al. Buteyko breathing technique reduces hyperventilation-induced hypocaponea and dyspnoea after exercise in asthma. American Thoracic Society International Conference. San Diego, CA. 2009:A3409. Not a study of breathing techniques.
11 Beth Israel Medical Center. Integrative medicine approach to the management of asthma in adults. clinicaltrials.gov. 2011. NCT00843544. Ongoing trial, no outcomes at time of review.
12 Bhikshapathi DVRN, Jayanthi C, Kishan V, et al. Influence of yogasanas on the physiology, therapy and theophylline pharmacokinetics in bronchial asthma patients. Acta Pharm Sci. 2007;49(2):187-94. Not a study of breathing techniques.
13 Bingol Karakoc G, Yilmaz M, Sur S, et al. The effects of daily pulmonary rehabilitation program at home on childhood asthma. Allergol Immunopathol (Madr). Jan. 2000;28(1):12-14. Other quality issues. [pmid: 10757852].
14 Birch M. Asthma and the Buteyko breathing method. Aust Nurs J. Mar. 2001;8(8):35. Synopsis of a potentially relevant study. [pmid: 11894574].
15 Birkel DA, Edgren L. Hatha yoga: improved vital capacity of college students. Altern Ther Health Med. Nov. 2000;6(6):55-63. Not one of specified study designs. [pmid: 11076447].
16 Bowler SD, Green A, Mitchell CA. Positive evidence of the effectiveness of Buteyko breathing techniques in asthma. Focus Alt Comp Ther. 1999;4:207-08. Synopsis of a potentially relevant study.
17 Brown JV, Demi AD, Wilson SR, et al. A home-based asthma education program for low-income families and their young asthmatic children. Am J Respir Crit Care Med. 2000;161(Suppl 3):A902. Not a study of breathing techniques.
18 Brown JV, Demi AS, Celano MP, et al. A home visiting asthma education program: challenges to program implementation. Health Educ Behav. Feb. 2005;32(1):42-56. Not a study of breathing techniques. [pmid: 15642753].
19 Brown JV, Bakeman R, Celano MP, et al. Home-based asthma education of young low-income children and their families. J Pediatr Psychol. Dec. 2002;27(8):677-88. Not a study of breathing techniques. [pmid: 12403858].
20 Bruton A. Breathing and relaxation training improves respiratory symptoms and quality of life in asthmatic adults. Aust J Physiother. 2008;54(1):76. Synopsis of a potentially relevant study. [pmid: 18298365].
21 Carvalho LC, Albuquerque HF, Pontes C, et al. Computerized Biofeedback Tool: Application in Electromyogram-Biofeedback. A New Beginning for Human Health. Annual International Conference of the IEEE Engineering in Medicine and Biology. 2003 Sep 17. Cancun, Mexico. 2003:1609-12. Not one of specified study designs.
22 Ceugniet F, Cauchefer F, Gallego J. Do voluntary changes in inspiratory-expiratory ratio prevent exercise-induced asthma?. Biofeedback Self Regul. Jun. 1994;19(2):181-88. Not a study of breathing techniques. [pmid: 7918755].
23 Ceugniet F, Cauchefer F, Gallego J. Voluntary decrease in breathing frequency in exercising asthmatic subjects. Eur Respir J. Nov. 1996;9(11):2273-79. Not one of specified interventions. [pmid: 8947071].
24 Chiang LC, Ma WF, Huang JL, et al. Effect of relaxation-breathing training on anxiety and asthma signs/symptoms of children with moderate-to-severe asthma: a randomized controlled trial. Int J Nurs Stud. Aug. 2009;46(8):1061-70. Not a study of breathing techniques. [pmid: 19246041].
25 Cooper SE, Oborne J, Newton S, et al. The effect of two breathing exercises (Buteyko and Pranayama) on the ability to reduce inhaled corticosteroids in asthma: a randomised controlled trial. American Thoracic Society 99th International Conference. 2003:B023. Unable to obtain, likely from another reviwed study.
26 Cowie RL, Conley DP, Underwood MF, et al. A randomized controlled trial of buteyko technique for asthma management. Proceedings of the American Thoracic Society. American Thoracic Society International Conference. 2006 May 19. San Diego, CA. 2006:A530. Unable to obtain, likely from another reviwed study.
27 Dahl J, Gustafsson D, Melin L. Effects of a behavioral treatment program on children with asthma. J Asthma. 1990;27(1):41-46. Not one of specified interventions. [pmid: 1968453].
28 Foglio K, Bianchi L, Bruletti G, et al. Long-term effectiveness of pulmonary rehabilitation in patients with chronic airway obstruction. Eur Respir J. Jan. 1999;13(1):125-32. Not a study of breathing techniques. [pmid: 10836336].
29 Girodo M, Ekstrand KA, Metivier GJ. Deep diaphragmatic breathing: rehabilitation exercises for the asthmatic patient. Arch Phys Med Rehabil. Aug. 1992;73(8):717-20. High or differential attrition. [pmid: 1642520].
30 Gomieiro LT, Nascimento A, Tanno LK, et al. Respiratory exercise program for elderly individuals with asthma. Clinics (Sao Paulo, Brazil). 2011;66(7):1163-69. Not one of specified study designs. [pmid: 21876968].
31 Goncalves RC, Nunes MPT, Cukier A, et al. Comparison between breathing exercises and aerobic conditioning on symptoms, quality of life and exhaled nitric oxide in asthmatic adults. Eur Respir J. 2006;28:370s. Not one of specified comparators.
32 Huntley AL, Marks GB. Sahaja yoga has limited effects in the management of asthma. Focus Alt Comp Ther. Sep. 2002;7(3):275-76. Only comparator includes relaxation training.
33 Janson-Bjerklie S, Clarke E. The effects of biofeedback training on bronchial diameter in asthma. Heart Lung. 1982;11(3):200-07. Published prior to 1990. [pmid: 6918383].
34 Kuiper D. Dysfunctional breathing and asthma Trial shows benefits of Buteyko breathing techniques. BMJ. Sep. 15. 2001;323(7313):631-32. Synopsis of a potentially relevant study. [pmid: 11575317].
35 Lehrer P, Hochron S, Carr R, et al. Biofeedback for increasing respiratory sinus arrhythmia as a treatment for asthma. 30th Annual Convention of the Association for the Advancement of Behavior Therapy. 1996 Nov 21. New York. New York. Association for the Advancement of Behavior Therapy. 1996. Not a study of breathing techniques.
36 Lehrer P, Carr RE, Smetankine A, et al. Respiratory sinus arrhythmia versus neck/trapezius EMG and incentive inspirometry biofeedback for asthma: a pilot study. Applied Psychophysiol Biofeedback. Jun. 1997;22(2):95-109. Other quality issues. [pmid: 9341966].
37 Lewis S, Cruft S, Egbagbe E, et al. A controlled trial of the effect of a breathing exercise device in asthma. Eur Respir J Suppl. 1996;9:337s. Synopsis of a potentially relevant study.
38 Lima EVN, Oliveira AN, Vieira RAF, et al. Inspiratory muscle training in children with asthma effect on muscle strength and pulmonary function. Eur Respir J. 2006;28:478s. Duplicate report of included study.
39 Manocha R, Marks GB, Kenchington P, et al. Sahaja yoga in the management of moderate to severe asthma: a randomised controlled trial. Thorax. Feb. 2002;57(2):110-15. Not one of specified interventions. [pmid: 11828038].
40 McConnell AK, Caine MP, et al. Inspiratory muscle training improves lung function and reduces exertional dyspnoea in mild/moderate asthmatics. Clin Sci. Suppl 39. 1998;95:4P. Followup less than 4 weeks.
41 McHugh P, Aitcheson F, Duncan B, et al. Buteyko Breathing Technique for asthma: an effective intervention. N Z Med J. Dec. 12. 2003;116(1187):U710. Only comparator includes relaxation training. [pmid: 14752538].
42 Meuret AE, Ritz T, Wilhelm FH, et al. Pco2 Biofeedback-Assisted Breathing Training for Panic Disorder and Asthma: Rationale and Empirical Findings. 64th Annual Scientific Conference of the American Psychosomatic Society. 2006 Mar 1. Denver. American Psychosomatic Society. 2008. Other quality issues.
43 Meuret AE, Ritz T, Wilhelm FH, et al. Targeting pCO(2) in asthma: pilot evaluation of a capnometry-assisted breathing training. Appl Psychophysiol Biofeedback. Jun. 2007;32(2):99-109. Other quality issues. [pmid: 17564826].
44 Mussell MJ, Hartley JP. Trachea-noise biofeedback in asthma: a comparison of the effect of trachea-noise biofeedback, a bronchodilator, and no treatment on the rate of recovery from exercise- and eucapnic hyperventilation-induced asthma. Biofeedback Self Regul. Sep. 1988;13(3):219-34. Published prior to 1990. [pmid: 3228551].
45 Nagarathna R, Nagendra HR. Yoga for bronchial asthma: a controlled study. Br Med J (Clin Res Ed). Oct. 19. 1985;291(6502):1077-79. Published prior to 1990. [pmid: 3931802].
46 Nagendra HR, Nagarathna R. Integrated approach of yoga therapy for seasonal and perennial bronchial asthma. IEEE/Engineering in Medicine and Biology Society Annual Conference. 1986:1759-62. Not one of specified study designs.
47 Neffen HE, Baena-Cagnani CE, Yanez A. Breathing Exercises for Asthmatic Children: Asthma Music and the Asthma Symphony. 16th World Congress of Asthma. Buenos Aires, Argentina. 1999:83-88. Unable to obtain, unlikely a trial.
48 Perrin JM, MacLean WE Jr, Gortmaker SL, et al. Improving the psychological status of children with asthma: a randomized controlled trial. J Dev Behav Pediatr. Aug. 1992;13(4):241-47. Not a study of breathing techniques. [pmid: 1506461].
49 Reuther I, Aldridge D. Qigong Yangsheng as a complementary therapy in the management of asthma: a single-case appraisal. J Altern Complement Med. 1998;4(2):173-83. Not one of specified study designs. [pmid: 9628207].
50 Ritz T, Meuret AE, Wilhelm FH, et al. Changes in pCO2, symptoms, and lung function of asthma patients during capnometry-assisted breathing training. Appl Psychophysiol Biofeedback. Mar. 2009;34(1):1-6. Other quality issues. [pmid: 19048369].
51 Sato K, Kawamura T, Abo T. “Senobi” stretch ameliorates asthma symptoms by restoring autonomic nervous system balance. J Investig Med. Dec. 2010;58(8):968-70. Not one of specified interventions. [pmid: 20930645].
52 Singh V, Wisniewski A, Britton J, et al. Effect of yoga breathing exercises (pranayama) on airway reactivity in subjects with asthma. Lancet. Jun. 9. 1990;335(8702):1381-83. Followup less than 4 weeks. [pmid: 1971670].
53 Slader CA, Reddel HK, Spencer LM, et al. Impact of breathing exercises on asthma symptoms and control. American Thoracic Society International Conference. San Diego, CA. 2005:D97. Duplicate report of included study.
54 Sodhi C, Singh S, Dandona PK. A study of the effect of yoga training on pulmonary functions in patients with bronchial asthma. Indian J Physiol Pharmacol. Apr. 2009;53(2):169-74. Other quality issues. [pmid: 20112821].
55 Stanton AE, Vaughn P, Carter R, et al. An observational investigation of dysfunctional breathing and breathing control therapy in a problem asthma clinic. J Asthma. 2008;45(9):758-65. Not one of specified study designs. [pmid: 18972291].
56 Stepans MB. Biofeedback and relaxation therapy: symptom control in individuals with lung disease. Communicating Nursing Research. 33rd Annual Communicating Nursing Research Conference/14th Annual WIN Assembly. Denver, CO. 2000:192. Patients with other respiratory diseases.
57 Thomas M. Are breathing exercises an effective strategy for people with asthma?. Nurs Times. Mar. 17. 2009;105(10):22-27. Duplicate report of included study. [pmid: 19400340].
58 Thomas M. Study of the effectiveness of breathing training exercises taught by a physiotherapist by either instructional videos/DVDs/internet download or by face-to-face sessions in the management of asthma in adults. Curr Control Trials. 2011. Ongoing trial, no outcomes at time of review.
59 Thomas M, McKinley RK, Prodger P, et al. Breathing retraining improves quality of life in asthmatic patients with dysfunctional breathing. Eur Respir J. 2001;18:330s. Duplicate report of included study.
60 Turner LA, Mickleborough TD, Tecklenburg S, et al. Inspiratory muscle training improves pulmonary function and reduces expiratory flow limitation in asthmatic individuals. 55th Annual Meeting on American College of Sports Medicine. Indianapolis, IN. 2008. No relevant outcomes.
61 Vedanthan PK, Kesavalu LN, Murthy KC, et al. Clinical study of yoga techniques in university students with asthma: a controlled study. Allergy Asthma Proc. Jan. 1998;19(1):3-9. Other quality issues. [pmid: 9532318].
62 Vijayaraghayan N. Role of yoga in the management of bronchial asthma. 6th World Congress on Holistic Life and Medicine. Calicut, India. 1996:137-40. Unable to obtain, unlikely a trial.
63 Weiner P, Magadle R, Beckerman M, et al. The relationship among inspiratory muscle strength, the perception of dyspnea and inhaled beta2-agonist use in patients with asthma. Can Respir J. Sep. 2002;9(5):307-12. No relevant outcomes. [pmid: 12410322].
64 Yarandi AN. Respiratory exercise and quality of life in asthmatic patients. Int J Hum Caring. Jun. 2006;10(2):78. Not one of specified study designs.