# Evidence Tables

Evidence Table 1a Study characteristics: hyperventilation reduction breathing techniques versus control

Evidence Table 1b Description of intervention groups: hyperventilation reduction breathing techniques versus control

Evidence Table 1c Change in asthma symptoms: hyperventilation reduction breathing techniques versus control

Evidence Table 1d Change in asthma medication use: hyperventilation reduction breathing techniques versus control

Evidence Table 1e Change in quality of life: hyperventilation reduction breathing techniques versus control

Evidence Table 1f Change in pulmonary function: hyperventilation reduction breathing techniques versus control

Evidence Table 2a Study characteristics: hyperventilation reduction breathing techniques versus nonhyperventilation reduction breathing techniques

Evidence Table 2b Description of intervention groups: hyperventilation reduction breathing techniques versus nonhyperventilation reduction breathing techniques

Evidence Table 2c Change in asthma symptoms: hyperventilation reduction breathing techniques versus nonhyperventilation reduction breathing techniques

Evidence Table 2d Change in asthma medication use: hyperventilation reduction breathing techniques versus nonhyperventilation reduction breathing techniques

Evidence Table 2e Change in quality of life: hyperventilation reduction breathing techniques versus nonhyperventilation reduction breathing techniques

Evidence Table 2f Change in pulmonary function: hyperventilation reduction breathing techniques versus nonhyperventilation reduction breathing techniques

Evidence Table 3a Study characteristics: yoga breathing technique versus control

Evidence Table 3b Description of intervention groups: yoga breathing techniques versus control

Evidence Table 3c Change in asthma symptoms: yoga breathing techniques versus control

Evidence Table 3d Change in asthma medication use: yoga breathing techniques versus control

Evidence Table 3e Change in quality of life: yoga breathing techniques versus control

Evidence Table 3f Change in pulmonary function: yoga breathing techniques versus control

Evidence Table 4a Study characteristics: inspiratory muscle training versus control

Evidence Table 4b Description of intervention groups: inspiratory muscle training versus control

Evidence Table 4c Change in asthma symptoms: inspiratory muscle training versus control

Evidence Table 4d Change in asthma medication use: inspiratory muscle training versus control

Evidence Table 4e Change in quality of life: inspiratory muscle training versus control

Evidence Table 4f Change in pulmonary function: inspiratory muscle training versus control

Evidence Table 5a Study characteristics: nonhyperventilation reduction breathing techniques versus control

Evidence Table 5b Description of intervention groups: nonhyperventilation reduction breathing techniques versus control

Evidence Table 5c Change in asthma symptoms: nonhyperventilation reduction breathing techniques versus control

Evidence Table 5d Change in asthma medication use: nonhyperventilation reduction breathing techniques versus control

Evidence Table 5e Change in quality of life: nonhyperventilation breathing techniques versus control

Evidence Table 5f Change in pulmonary function: nonhyperventilation reduction breathing techniques versus control