# Search Strategies

Database: AltHealthWatch
S16 | S1 and S15
S15 | S2 or S3 or S4 or S5 or S6 or S7 or S8 or S9 or S10 or S11 or S12 or S13 or S14
S14 | TI biofeedback or AB biofeedback
S13 | TI diaphragmatic breath* or AB diaphragmatic breath*
S12 | AB ( diaphragm* ) and AB ( exercise* or training or retraining or pattern* or technique* )
S11 | AB ( breath* or respirat* ) and AB ( exercise* or training or retraining or pattern* or technique* )
S10 | TI ( breath* or respirat* ) and TI ( exercise* or training or retraining or pattern* or technique* )
S9 | TI ( breath* or respirat* ) and TI ( paced or pursed )
S8 | AB ( breath* or respirat* ) and AB ( paced or pursed )
S7 | AB ( breath* or respirat* ) and AB ( physiotherap* or physical therap* )
S6 | TI ( breath* or respirat* ) and TI ( physiotherap* or physical therap* )
S5 | TI Pranayama or AB Pranayama
S4 | TI Buteyko or AB Buteyko
S3 | TI yogic OR AB yogic
S2 | TI yoga OR AB yoga
S1 | TI asthma* or AB asthma*

Database: AMED (Allied and Complementary Medicine) <1985 to December 2011>
1 | asthma/
2 | asthma$.ti,ab.
3 | 1 or 2
4 | breathing exercises/
5 | yoga/
6 | Yoga.ti,ab.
7 | yogic.ti,ab.
8 | Buteyko.ti,ab.
9 | Pranayama.ti,ab.
10 | Papworth.ti,ab.
11 | “inspiratory muscle training”.ti,ab.
12 | “expiratory muscle training”.ti,ab.
13 | ((breath$ or respirat$) adj5 (physiotherap$ or physical therap$)).ti,ab.
14 | ((breath$ or respirat$) adj5 (paced or pursed)).ti,ab.
15 | ((breath$ or respirat$) adj5 (exercise$ or training or retraining or pattern$ or technique$)).ti,ab.
16 | (diaphragm* and (exercise$ or training or retraining or pattern$ or technique$)).ti,ab.
17 | diaphragmatic breath$.ti,ab.
18 | biofeedback/
19 | biofeedback.ti,ab.
20 | or/4–19
21 | 3 and 20
22 | limit 21 to yr=“1990 -Current”
23 | limit 22 to english

Database: CINAHL
S27 | S3 and S25 Limiters - Published Date from: 19900101-20111231
S26 | S3 and S25
S25 | S4 or S5 or S6 or S7 or S8 or S9 or S10 or S11 or S12 or S13 or S14 or S15 or S16 or S17 or S18 or 19 or S20 or S21 or S22 or S23 or S24
S24 | TI biofeedback or AB biofeedback
S23 | (MH “Biofeedback”) OR (MH “Biofeedback (Iowa NIC)”)
S22 | TI diaphragmatic breath* or AB diaphragmatic breath*
S21 | TI diaphragm* and TI ( exercise* or training or retraining or pattern* or technique* )
S20 | AB diaphragm* and AB ( exercise* or training or retraining or pattern* or technique* )
S19 | AB ( breath* or respirat* ) and AB ( exercise* or training or retraining or pattern* or technique* )
S18 | TI ( breath* or respirat* ) and TI ( exercise* or training or retraining or pattern* or technique* )
S17 | TI ( breath* or respirat* ) and TI ( paced or pursed )
S16 | AB ( breath* or respirat* ) and AB ( paced or pursed )
S15 | AB ( breath* or respirat* ) and AB ( physiotherap* or physical therap* )
S14 | TI ( breath* or respirat* ) and TI ( physiotherap* or physical therap* )
S13 | TI “expiratory muscle training” or AB “expiratory muscle training”
S12 | TI “inspiratory muscle training” or AB “inspiratory muscle training”
S11 | TI Papworth or AB Papworth
S10 | TI Pranayama or AB Pranayama
S9 | TI Buteyko or AB Buteyko
S8 | TI yogic or AB yogic
S7 | TI yoga or AB yoga
S6 | (MH “Yoga”) OR (MH “Yoga Pose”)
S5 | (MH “Breathing Exercises (Saba CCC)”)
S4 | (MH “Breathing Exercises”) OR (MH “Buteyko Method”)
S3 | s1 or s2
S2 | TI asthma* or AB asthma*
S1 | (MH “Asthma”) OR (MH “Asthma, Exercise-Induced”) OR (MH “Status Asthmaticus”)

Database: Cochrane Central Register of Controlled Trials
#1 | asthma*:ti,ab,kw
#2 | “breathing exercises”:ti,ab,kw
#3 | yoga:ti,ab,kw
#4 | yogic:ti,ab,kw
#5 | Buteyko:ti,ab,kw
#6 | Pranayama:ti,ab,kw
#7 | Papworth:ti,ab,kw
#8 | “inspiratory muscle training”:ti,ab,kw
#9 | “expiratory muscle training”:ti,ab,kw
#10 | breath*:ti or respirat*:ti
#11 | physiotherap*:ti or physical therap*:ti
#12 | (#10 AND #11)
#13 | breath*:ab or respirat*:ab
#14 | physiotherap*:ab or physical therap*:ab
#15 | (#13 AND #14)
#16 | paced:ti,ab or pursed:ti,ab
#17 | (( #11 OR #14 ) AND #16)
#18 | exercise*:ti or training:ti or retraining:ti or pattern*:ti or technique*:ti
#19 | (#10 AND #18)
#20 | exercise*:ab or training:ab or retraining:ab or pattern*:ab or technique*:ab
#21 | (#13 AND #20)
#22 | diaphragm*:ti,ab
#23 | (#22 AND ( #18 OR #20 ))
#24 | diaphragmatic next breath*
#25 | biofeedback:ti,ab,kw
#26 | (#2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #12 OR #15 OR #17 OR #19 OR #21 OR #23 OR #24 OR #25)
#27 | (#1 AND #26), from 1990 to 2011

Database: CSA
KW=asthma AND KW=(Buteyko OR Pranayama OR Papworth OR yoga OR yogic OR biofeedback OR “inspiratory muscle training” OR “expiratory muscle training” OR “breathing physical therapy” OR “breathing physiotherapy” OR paced OR pursed OR “breathing exercise*” OR “breathing training” OR “breathing retraining” OR “diaphragmatic breathing” OR “breathing technique*”)

Database: EMBASE <1988 to 2011 July 28>
1 | asthma/ or allergic asthma/ or asthmatic state/ or exercise induced asthma/ or extrinsic asthma/ or intrinsic asthma/ or mild intermittent asthma/ or mild persistent asthma/ or moderate persistent asthma/ or nocturnal asthma/ or occupational asthma/ or severe persistent asthma/ (112140)
2 | asthma$.ti,ab.
3 | 1 or 2
4 | breathing exercise/
5 | YOGA/
6 | yoga.ti,ab.
7 | yogic.ti,ab.
8 | Buteyko.ti,ab.
9 | Pranayama.ti,ab.
10 | Papworth.ti,ab.
11 | “inspiratory muscle training”.ti,ab.
12 | “expiratory muscle training”.ti,ab.
13 | ((breath$ or respirat$) adj5 (physiotherap$ or physical therap$)).ti,ab.
14 | ((breath$ or respirat$) adj5 (paced or pursed)).ti,ab.
15 | ((breath$ or respirat$) adj5 (exercise$ or training or retraining or pattern$ or technique$)).ti,ab.
16 | (diaphragm* and (exercise$ or training or retraining or pattern$ or technique$)).ti,ab.
17 | diaphragmatic breath$.ti,ab.
18 | feedback system/
19 | biofeedback.ti,ab.
20 | or/4–19
21 | 3 and 20
22 | limit 21 to yr=“1990 -Current”
23 | limit 22 to english language

Database: IndMED
asthma
AND
buteyko OR
yoga OR
yogic OR
papworth OR
pranayama OR
biofeedback OR
expiratory muscle training OR
inspiratory muscle training OR
breathing physical therapy OR
breathing physiotherapy OR
paced OR
pursed OR
breathing exercise OR
breathing exercises OR
breathing training OR
breathing retraining OR
diaphragm breathing OR
breathing technique OR
breathing techniques OR
breathing pattern OR
breathing patterns

Database: Mantis <1880 to December 2010>
1 | asthma$.mp. [mp=title, abstract, descriptors]
2 | yoga.mp. [mp=title, abstract, descriptors]
3 | yogic.mp. [mp=title, abstract, descriptors]
4 | Buteyko.mp. [mp=title, abstract, descriptors]
5 | Pranayama.mp. [mp=title, abstract, descriptors]
6 | Papworth.mp. [mp=title, abstract, descriptors]
7 | “inspiratory muscle training”.mp. [mp=title, abstract, descriptors]
8 | “expiratory muscle training”.mp. [mp=title, abstract, descriptors]
9 | ((breath$ or respirat$) adj5 (physiotherap$ or physical therap$)).mp. [mp=title, abstract, descriptors]
10 | ((breath$ or respirat$) adj5 (paced or pursed)).mp. [mp=title, abstract, descriptors]
11 | ((breath$ or respirat$) adj5 (exercise$ or training or retraining or pattern$ or technique$)).mp. [mp=title, abstract, descriptors]
12 | (diaphragm* and (exercise$ or training or retraining or pattern$ or technique$)).mp. [mp=title, abstract, descriptors]
13 | diaphragmatic breath$.mp. [mp=title, abstract, descriptors]
14 | biofeedback.mp. [mp=title, abstract, descriptors]
15 | or/2–14
16 | 1 and 15
17 | limit 16 to yr=“1990 -Current”

Database: Ovid MEDLINE(R)
1 | asthma/ or asthma, exercise-induced/ or status asthmaticus/
2 | asthma$.ti,ab.
3 | 1 or 2
4 | Breathing Exercises/
5 | Yoga/
6 | yoga.ti,ab.
7 | yogic.ti,ab.
8 | Buteyko.ti,ab.
9 | Pranayama.ti,ab.
10 | Papworth.ti,ab.
11 | “inspiratory muscle training”.ti,ab.
12 | “expiratory muscle training”.ti,ab.
13 | ((breath$ or respirat$) adj5 (physiotherap$ or physical therap$)).ti,ab.
14 | ((breath$ or respirat$) adj5 (paced or pursed)).ti,ab.
15 | ((breath$ or respirat$) adj5 (exercise$ or training or retraining or pattern$ or technique$)).ti,ab.
16 | (diaphragm* and (exercise$ or training or retraining or pattern$ or technique$)).ti,ab.
17 | diaphragmatic breath$.ti,ab.
18 | biofeedback, psychology/
19 | biofeedback.ti,ab.
20 | 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19
21 | 3 and 20
22 | limit 21 to yr=“1990 -Current”
23 | remove duplicates from 22
24 | limit 23 to english language

Database: PEDRO
asthma
AND
buteyko OR
yoga OR
yogic OR
papworth OR
pranayama OR
biofeedback OR
expiratory muscle training OR
inspiratory muscle training OR
breathing physical therapy OR
breathing physiotherapy OR
paced OR
pursed OR
breathing exercise OR
breathing training OR
breathing retraining OR
diaphragm breathing OR
breathing technique OR
breathing pattern

Database: PsychINFO
1 | asthma/
2 | asthma$.ti,ab.
3 | 1 or 2
4 | yoga/
5 | yoga.ti,ab.
6 | yogic.ti,ab.
7 | Buteyko.ti,ab.
8 | Pranayama.ti,ab.
9 | Papworth.ti,ab.
10 | “inspiratory muscle training”.ti,ab.
11 | “expiratory muscle training”.ti,ab.
12 | ((breath$ or respirat$) adj5 (physiotherap$ or physical therap$)).ti,ab.
13 | ((breath$ or respirat$) adj5 (paced or pursed)).ti,ab.
14 | ((breath$ or respirat$) adj5 (exercise$ or training or retraining or pattern$ or technique$)).ti,ab.
15 | (diaphragm* and (exercise$ or training or retraining or pattern$ or technique$)).ti,ab.
16 | diaphragmatic breath$.ti,ab.
17 | biofeedback/ or biofeedback training/
18 | biofeedback.ti,ab.
19 | or/4–18
20 | 3 and 19
21 | limit 20 to yr=“1990 -Current”
22 | limit 21 to english language