# Abbreviations and Acronyms

AHRQ: Agency for Healthcare Research and Quality
AMED: Allied and Complementary Medicine
AQLQ: Asthma Quality of Life Questionnaire
ATS: American Thoracic Society
BTS: British Thoracic Society
CAM: complementary and alternative medicine
CCRCT: Cochrane Central Register of Controlled Trials
CI: confidence interval
CO_2_: carbon dioxide
EPC: Evidence-based Practice Center
FEV_1_: forced expiratory volume in 1 second
FVC: forced vital capacity
HRV: heart rate variability
ICS: inhaled corticosteroid(s)
IMT: inspiratory muscle training
IndMED: Indian Medical Journals
LOCF: last observation carried forward
MANTIS: Manual, Alternative and Natural Therapy Index System
mcg: microgram(s)
NAEPP: National Asthma Education Program and Prevention
PEDro: Physiotherapy Evidence Database
PEF: peak expiratory flow
RCT: randomized controlled trial
SABA: short-acting beta_2_-agonists
SF: Short Form Health Survey (e.g., SF-36)
SGRQ: St. George’s Respiratory Questionnaire
SIP: scientific information packet
SMD: standardized mean difference
TEP: technical expert panel
VC: vital capacity