# Technical Expert Panel

Carrie Malhotra-Ortiz

W.L. Gore & Associates

Flagstaff, AZ

Patrick O’Dwyer, M.B., M.D., FRCS

University of Glasgow

Glasgow, Scotland, UK

Guy Voeller, M.D., FACS

UT Medical Group

Germantown, TN

Kasper Wang, M.D., FACS, FAAP

University of Southern California School of Medicine

Los Angeles, CA