# Results

## Overall Description of Included Studies

Searches identified 2,722 potentially relevant articles and we excluded 1,878 of these at the abstract level (Figure 2). A large number of these exclusions (560) were because the study was not published in English. We had employed this exclusion solely for practical purposes, and an important issue is whether including non-English studies would have influenced any of the conclusions of our review. Thus, below, in the summary of each Key Question, we discuss the non-English abstracts that may have been included for that Key Question.

Figure 2 Literature flow diagram

The figure shows the counts of articles at various stages of searching. The box at the top stated that searches identified 2,537 articles that were potentially relevant. Screening of abstracts excluded 1,733 of these, for many different reasons, which are listed in the upper right box. The counts of different reasons were 549 for not English, 462 for case series, 327 for “did not address any Key Question,” 173 for background/commentary/protocol/guideline/review, 42 for “did not focus sufficiently on a patient population of interest,”42 for incarcerated or strangulated hernia, 3 for “nonrandomized study that did not attempt to correct for selection bias,” 3 for exact duplicate of other included article, 2 for abstract only, and 130 for other reasons. We ordered 804 articles in full for possible inclusion. At this level, 597 articles were excluded, for many different reasons listed in the box in the middle right. The counts of different reasons were 252 for “did not address any Key Question,” 80 for background/commentary/protocol/guideline/review, 76 for case series, 76 for “nonrandomized study that did not attempt to correct for selection bias,” 12 for “did not report any outcomes of interest,” 11 for “did not focus sufficiently on a patient population of interest,” 8 for “did not report data comparing the procedures,” 5 for abstract only, 1 for not English, and 76 for other reasons. The box at the bottom indicates that we included a total of 207 articles, which described 141 unique studies. The box also indicate the study counts for different Key Questions, which were 2 for Key Question 1,37 for Key Question 2a, 6 for Key Question 2b, 8 for Key Question 2c, 21 for Key Question 3, 9 for Key Question 4, 29 for Key Question 5, 19 for Key Question 6, 32 for Key Question 7, 0 for Key Question 8, and 2 for Key Question 9. The box also indicates that these counts do not add to 141 because some studies were included for multiple Key Questions.

At the full-article level, we excluded another 621 articles, typically due to irrelevance to any of our Key Questions (252 publications), background/review/commentary/protocol articles (80 publications), uncontrolled design (81 publications), or nonrandomized designs without any attempt to control for selection bias (79 publications). An alphabetized list of these 621 exclusions, along with the reason for exclusion, appears in Appendix B.

There remained 223 publications describing 151 unique studies that we included in our review (Table 1). Multiple publications of a given study typically involved reporting additional outcomes not reported in the original publication, longer followup time points, subgroup analyses, or additional clarification of study methods; all such publications were included, and in evidence tables we grouped together all of the study's citations. The largest number of studies addressed Key Question 2a (38 studies), which compared open mesh repair to laparoscopic mesh repair in patients with primary inguinal hernia. Other large evidence bases were found for Key Question 3 (comparing different procedures for open mesh repair, 21 studies), Key Question 5 (comparing meshes, 32 studies), and Key Question 7 (the association between prior surgical experience and RC, in the context of laparoscopic hernia repair, 32 studies). No studies were identified for Key Question 8 (comparing surgical exploration vs. WW for pediatric contralateral inguinal hernia). Sixteen studies were included for multiple Key Questions (e.g., two studies were each included for four Key Questions), because they included three or more groups or reported subgroup analyses. A list of the included studies, along with marks identifying which studies addressed which questions, appears in Table 2 in Appendix C.

Table 1 Overview of included studies

Key Question | # Included Studies | Study Designs | Length of Followup
1 (pain-free hernia) | 2 | RCTs, 877 patients | 1–4 years
2a (open mesh vs. lap. mesh in primary hernia) | 38 | 36 RCTs, 10,949 patients 2 CTs, 168,389 patients | 3 days to 7.4 years
2b (open mesh vs. lap. mesh in bilateral hernia) | 6 | 5 RCTs, 599 patients 1 CT, 3,202 patients | 1 year to 18 months
2c (open mesh vs. lap. mesh in recurrent hernia) | 8 | 6 RCTs, 641 patients 2 CTs, 17,516 patients | 2–5.3 years
3 (open mesh vs. open mesh) | 21 | 20 RCTs, 4,259 patients 1 CT, 127,535 patients | 1 week to 7.4 years
4 (lap. mesh vs. lap. mesh) | 11 | RCTs, 1,378 patients | 2 days to 7.4 years
5 (comparing meshes) | 32 | RCTs, 5,292 patients | 3 weeks to 5 years
6 (comparing mesh fixation methods) | 23 | 22 RCTs, 3,599 patients 1 CT, 82,015 patients | 1 week to 7 years
7 (surgical experience and hernia recurrence) | 32 | 6 RCTs, 4,020 patients 8 CTs, 17,965 patients 18 CSs, 17,832 patients | 3 months to 10 years
8 (contralateral exploration vs. watchful waiting) | 0 | NA | NA
9 (pediatric open vs. lap.) | 2 | RCTs, 172 patients | 1–2 years

CSs = case series; CT = nonrandomized controlled trial; lap. = laparoscopic; NA = Not applicable; RCTs = randomized controlled trials

Only 16 of 151 studies (10 percent) were conducted exclusively in the United States. An additional 19 studies (12 percent) were conducted in the United Kingdom, Australia, Canada, United States/United Kingdom, or United States/Canada. The remaining 116 studies (77 percent) were conducted in other countries, most prominently Germany (14 studies or 9 percent), Turkey (12 studies or 8 percent), India (11 studies or 7 percent), and Italy (11 studies or 7 percent).

Eleven sections follow, one for each Key Question (Key Question 2 is actually three questions: 2a, 2b, and 2c). Each section is structured in the same manner: (1) an overview of study characteristics for the studies included for that Key Question; (2) a discussion of risk of bias of those particular studies; (3) a summary of findings (including summaries of relevant meta-analyses); (4) a discussion of the applicability of those studies; and (5) a summary (which includes a list of our conclusions for that Key Question, an SOE table, and a discussion of excluded non-English abstracts). All figures displaying meta-analyses are listed in the Figures section, which appears after the References. All evidence tables are in Appendix C, sorted by Key Question (i.e., all of the Key Question 1 tables appear first, then all of the Key Question 2a tables, etc.).

## Key Question 1 Pain-free hernia: Does hernia repair differ from watchful waiting in patient-oriented effectiveness outcomes and/or adverse events?

### Study Characteristics

General information about the two studies included for this Key Question appears in Table 3 of Appendix C. One study was conducted in the United States and Canada and the other in the United Kingdom. The North American study was a randomized controlled trial (RCT) with more than three centers and the United Kingdom study was a single-center RCT. Both studies compared mesh repair with WW. The RCTs enrolled 720 patients and 157 patients, respectively. In the multi-center study, surgeries were performed between 1999 and 2004 at three university hospitals and two community clinics.12,44-49 This study was funded by AHRQ and the American College of Surgeons, and the lead author disclosed financial ties with a manufacturer of a mesh plug. The other single-center study conducted at a university hospital did not report the date range of the surgeries or source of funding.50,51

Patient enrollment criteria appear in Appendix C in Table 4 (hernia-related criteria), Table 5 (demographic and medical criteria), and Table 6 (other criteria). Enrollment criteria varied widely among both studies. The hernia-related study exclusion criteria in the studies include irreducible hernia (one study), incarcerated hernia (both studies), and femoral hernia (both studies). Regarding patient age criteria, the two studies enrolled patients aged >18 and >55 years of age, respectively. In addition, one study excluded patients unfit for general anesthesia or those with anesthesia risk scores of 3 or 4 or more; the other study excluded patients with infection and all female patients.

Treatment details appear in Table 7 of Appendix C. In one study, mesh repair was performed by the standardized Lichtenstein open tension-free repair as described by Amid52 under local or general anesthesia. The other study did not report the detail of the “tension-free mesh repair” procedure. Neither of the studies reported the actual number of prior laparoscopic hernia repairs the surgeons had performed. Instead, studies either didn't mention their prior experience, or simply said the surgeon had general experience in hernia repair.

All reported baseline patient characteristics in the studies included for this Key Question appear in Table 8 of Appendix C. The mean age of the patients ranged from 57.5 to 71.9 years; most patients were male with primary hernias. One study reported medical comorbidities including congestive cardiac failure, prior myocardial infarction, hypertension, chronic obstructive pulmonary disease, chronic cough, prostatism, and diabetes.

### Risk of Bias

Our risk-of-bias assessments for both studies appear in Table 9 of Appendix C. One RCT was categorized as Moderate risk of bias for all reported outcomes and the other as either Low (for the outcomes of recurrence, health care utilization, adverse events) or Moderate risk of bias (for pain and QOL). Many reasons underlie the Moderate rating for the two studies that addressed this Key Question. Common reasons involved concealment of allocation (either not performed or not reported), use of subjective outcome measures (pain and QOL), and the blinding of outcome assessors (either not performed or not reported).

### Findings

All included data for this Key Question appear in Table 10 of Appendix C.

#### Quality of Life

One study reported the QOL data on an intention-to-treat basis using the SF-36 instrument.50,51 At 6 months, the surgical group fared better than the WW group on “general health” and “overall change in health status in the previous 12 months” (mean group difference 5.8, 95% CI, 0.1 to 11.5; mean group difference 9.4, 95% CI, 3.6 to 15.1, respectively). At 12 months, the surgical group still fared better than the WW group on “overall change in health status in the previous 12 months” (mean group difference, 7.3; 95% CI, 0.4 to 14.3; p=0.039). There were no statistically significant differences on other SF-36 items at both 6 and 12 months.

#### Long-Term Pain

The two studies reviewed for Key Question 1 used different measures for comparing long-term pain (>6 months after surgery). One study reported group differences at 2 years for pain interfering with activities among the intention-to-treat patients. On intention-to-treat analysis, percentage of patients with pain interfering among the surgical group was 2.2 percent compared with 5.1 percent in the WW group. This difference was not statistically significant (OR=0.42; 95% CI, 0.17 to 1.04), but also did not indicate equivalence.12,44-49 The second study compared the pain (measured in VAS) scores at rest and at movement between the two groups.50 They reported no statistically significant difference in mean pain (measured in VAS) scores at rest (difference in means = -1.5; 95% CI, -4.8 to 1.8) and at movement (difference in means = -1.5; 95% CI, -6.1 to 2.3) at 12 months. The low precision precludes any conclusion for this outcome.

#### Adverse Events

We conducted a meta-analysis of acute hernia/strangulation (Figure 3); the evidence was inconclusive, because it was too imprecise to reveal the direction of effect.

Figure 3 Key Question 1: Meta-analysis of acute hernia/strangulation

(I^2^=30%, tau=1.08)

The figure shows the results of a meta-analysis comparing mesh repair and watchful waiting on the outcome Acute Hernia/Strangulation in the context of pain-free hernia in adults. Points to the left of the midline favor mesh repair, whereas points to the right of the midline favor watchful waiting. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

### Applicability

Two studies are included for review for Key Question 1. We evaluated the studies to identify factors that could potentially affect the applicability of the evidence. As described in the Methods section, the goal of the evaluation is to raise stakeholders' attention to potential applicability issues embedded in the evidence rather than generating a rating or score for the applicability.

Among the two studies, the Fitzgibbons study compared WW with the Lichtenstein procedure,12,44-49 while the O'Dwyer study compared WW with “tension-free mesh repair.”50,51 The findings of the studies may not apply to the comparison between other hernia repair procedures (e.g., TAPP or TEP) and WW. Meanwhile, both studies were published in 2006 and may not necessarily reflect the comparative performance of the procedures that are performed currently. Neither of the two studies discussed surgeons' prior experience for the surgeries being studied. Therefore, it is unclear whether there are any applicability issues related to the surgeons' level of experience.

Both the Fitzgibbons and O'Dwyer studies excluded patients with incarcerated, strangulated, or femoral hernia. Therefore, the findings of the studies may have an applicability issue for these patients. The two studies also used other enrollment criteria to exclude certain types of patients. For example, the O'Dwyer study did not include patients younger than 55 years of age, and the Fitzgibbons study did not include female patients. Other patient enrollment criteria used in the two studies are provided in Appendix C in Table 4 and Table 6. It is unclear how these enrollment criteria and patients characteristics may affect the applicability of the evidence.

The Fitzgibbons study was conducted in five medical centers in North America (four in the United States and one in Canada). Three of the centers are affiliated with a university and the other two are community medical centers. The O'Dwyer study was conducted in a university hospital in the United Kingdom. Based on the data reported, it is unclear if the geographic or clinical settings of the two studies have any implication in determining the applicability of the evidence. Detailed information on geographic and clinical settings of the two studies is provided in Table 3 of Appendix C.

### Summary of Key Question 1

A summary of the comparisons and outcomes we examined in this Key Question is provided in Table 2 below. The evidence was sufficient to permit a conclusion for one outcome:

- Quality of life at 6 months and 1 year was greater for patients who had received mesh repair than for those who were on WW.

Table 2 Key Question 1: Strength of evidence ratings

Comparison | Outcome | # Studies | Overall Risk of Bias | Consistency | Directness | Precision | Evidence Favors | SOE Rating
Mesh repair vs. watchful waiting | Acute hernia/strangulation | 2 | MOD | C | D | I OR 0.77 (CI 0.06 to 10.8) | ? | INSUFF
Mesh repair vs. watchful waiting | Long-term pain at rest (measured in VAS at 2 years after trial entry) | 1 | MOD | U | D | I Diff in means -1.5 (CI -4.8 to 1.8) | ? | INSUFF
Mesh repair vs. watchful waiting | Long-term pain during movement (measured in VAS at 2 years after trial entry) | 1 | MOD | U | D | I Diff in means -1.5 (CI -6.1 to 2.3) | ? | INSUFF
Mesh repair vs. watchful waiting | Long-term pain interfering with activities (intention-to-treat) (measured in VAS at 2 years after trial entry) | 1 | MOD | U | D | I OR 0.42 (CI 0.17 to 1.04) | ? | INSUFF
Mesh repair vs. watchful waiting | Quality of life at 1 year (measured as overall change in health status in previous 12, months using the SF-36) | 1 | MOD | U | D | P (reported 95% CI, difference in means 7.3, CI 0.4 to 14.3) | Mesh plug repair | LOW

CI = Confidence interval; Diff = difference, OR = odds ratio, SOE = strength of evidence; VAS = visual analog scale.

Note:

For consistency, C = consistent, I = inconsistent, U = unknown consistency because there was only one study.

For directness, D = direct and I = indirect.

For precision, I = imprecise, P = precise.

For the column labeled “Evidence favors,” ? denotes inconclusive evidence, and EQ denotes approximate equivalence.

Our ratings of the SOE for this outcome also appear in the Table. The factors influencing our assessment of the SOE include the following: the study was at Moderate risk of bias for pain (see the pertinent section above); the consistency is unknown; the outcome is directly important to clinicians and patients; the results are imprecise. We examined the studies that had been excluded for being non-English, and none of them would have been included for this Key Question.

In the Summary of Key Question 1, we looked through the list of non-English articles excluded for being non-English and found none relevant to this Key Question.

## Key Question 2a Does open hernia repair with a mesh differ from laparoscopic hernia repair with a mesh in patient-oriented effectiveness outcomes and/or adverse events? Primary hernias

### Study Characteristics

General information about the 38 studies included for this Key Question appears in Table 11 of Appendix C. Seven were conducted in Turkey; five in Sweden; three each in Finland, Germany, and the United States; two each in China, the Netherlands, and the United Kingdom; and the rest in other countries. Twenty were single-center randomized trials; four were two-center randomized trials; seven were RCTs with more than three centers; two were country-wide registry studies (one in Denmark and one in Sweden); and the remaining five were RCTs that did not report the number of centers.

Regarding specific surgical procedures, the most commonly compared procedures were TAPP versus Lichtenstein (14 studies), TEP versus Lichtenstein (14 studies), TAPP versus mesh plug (three studies), TEP versus mesh plug (three studies), and TAPP/TEP versus Lichtenstein (four studies). The RCTs enrolled between 38 and 2,164 patients each; the Swedish registry included 174,527 hernias; and the Danish registry included 67,306 hernias. The dates of patient enrollment were reported by 32 of 38 studies. The average length of the enrollment period was 1.9 years (range 6 months to 14 years). Studies were typically conducted in the mid-1990s and early 2000s.

Fourteen studies were conducted at university hospitals; 13 more were conducted at general and nonuniversity hospitals; five included some university hospitals as well as some nonuniversity hospitals; the remaining six did not report the type(s) of hospitals. Funding for the study was not reported by 26 studies; government funding was reported in six studies; university funding was reported in two studies; three did not report the funding source but did state they had no manufacturer ties; two did report partial manufacturer funding (and one of these stated that the manufacturer had no role in the design, conduct, or analysis of the study). Patient enrollment criteria appear in Appendix C in Table 12 (hernia-related criteria), Table 13 (demographic and medical criteria), and Table 14 (other criteria).

Enrollment criteria varied widely among the 37 studies. The most commonly used hernia-related exclusions were recurrent hernia (20 studies), bilateral hernia (18 studies), and incarcerated hernia (16 studies). Others were femoral hernia (excluded by six studies), “emergency” hernia (excluded by five studies), and scrotal hernia (excluded by four studies). Overall, the studies paint an extraordinarily diverse portrait of the types of hernias deemed relevant to the studies, even though, by virtue of inclusion, they all compared open repair of inguinal hernia to laparoscopic repair of inguinal hernia.

Regarding patient age criteria, 30 of the 38 studies (79 percent) stated that they included any adults or required age >18 years. Twenty-three (61 percent) excluded those unfit for general anesthesia or those with anesthesia risk scores of 3 or 4 or more, and 17 studies excluded those who had undergone a prior surgery in the lower abdomen. Sixteen studies excluded all females, eight excluded pregnant women, and seven excluded those with coagulation disorders. As with the hernia-related exclusions, a large variability existed in how studies selected patients for inclusion.

Treatment details appear in Table 15 of Appendix C. Laparoscopic treatments were TAPP for 13 studies, TEP for 15 studies, and both TAPP and TEP in the remaining 10 studies. Laparoscopic repair invariably used general anesthesia, and the use of staples was the norm (with some surgeons stapling selectively). Mesh sizes varied widely, from smaller meshes at 7 by 10 cm to larger, 15 by 15 cm meshes; the typical mesh size was between these extremes, such as 10 by 14 cm. None of the studies reported the actual number of prior laparoscopic hernia repairs the surgeons had performed. Instead, studies either didn't mention their prior experience, or simply said surgeons had general laparoscopic skills that were not specific to hernia repair. Five of the 38 studies stated that “all surgeons had performed at least X prior procedures” of the type performed in the study (with X values of 5, 10, 10, 25, and 100 in the five studies).

Open hernia repairs were mostly Lichtenstein, and meshes were typically secured with sutures. The type of anesthesia was highly variable, with seven studies reporting general anesthesia for all patients, another six only using local or regional anesthesia, and seven others reporting that any type of anesthesia could be used depending on the preference of the patient, surgeon or anesthesiologist. Mesh sizes were variable, with the smallest mesh 6 by 8 cm, and the largest mesh15 by 15 cm, and the most typical size 7 by 12cm.

All reported baseline patient characteristics in the studies included for this Key Question appear in Table 16 of Appendix C. A summary of the most commonly reported baseline characteristics in studies included for Key Questions 2 through 7 appears in Table 3 below (we considered these Key Questions together because they addressed similar populations). The typical patient was a man in his mid-50s with a BMI of 25.3 kg/m^2^ (which corresponds to 172 pounds in a male of average height). About a quarter of these men worked in physically strenuous jobs such as manual labor (among the 25 studies reporting this characteristic). This characteristic may be important in the context of hernia surgery because the persistence of symptoms is more likely to delay one's return to physical work than to more sedentary work. In the typical study, most patients had a primary unilateral hernia; slightly under half had an indirect hernia; slightly over half had a right-side hernia.

Table 3 Summary of baseline characteristics

Characteristic | Number of Studies From Key Questions 2-7 Reporting This Characteristic | Median | IQR
Percentage male | 107 | 96% males | 92%-100%
Age | 132 | 54 years old | 49–58
Body mass index | 39 | 25.3 kg/m^2^ | 25.0–26.7
Percentage physically strenuous job | 22 | 26% | 21%–42%
Percentage primary | 115 | 100% | 89%–100%
Percentage unilateral | 101 | 93% | 76%–100%
Percentage indirect | 65 | 45% | 34%–55%
Percentage right-side | 42 | 53% | 47%–58%

IQR = Interquartile range.

### Risk of Bias

Our risk-of-bias assessments for the 38 studies appear in Table 17 of Appendix C. The 36 RCTs were all categorized as Moderate risk of bias for all of their reported outcomes, and the two registry studies that were both categorized as High risk of bias. The latter two were retrospective and nonrandomized studies that had no concealment of allocation, outcomes assessed with knowledge of treatment, and potentially other differences between the compared groups that may have influenced the registry findings.

Many reasons underlie the Moderate rating for the 36 RCTs. A common reason was that the surgeons may have had much more experience performing the study's open hernia repair procedures than the study's laparoscopic hernia repair procedures. This difference in prior experience could potentially explain differences in patient outcomes among those who received open versus laparoscopic repair. Only three of the 36 RCTs stated that the surgeons were highly experienced with both types of repair used in the study. Most studies did not report prior experience with the procedures being compared, and a few studies made clear that the surgeons' prior experience was much greater with open repair. Two other common reasons involved concealment of allocation (either not performed or not reported by 18 studies) and the blinding of outcome assessors (either not performed or not reported for more than 90 percent of the studies' data points).

### Findings

All included data for this Key Question appear in Table 18 of Appendix C.

#### Hernia Recurrence

We performed a meta-analysis of the 30 studies reporting this outcome, and found that recurrence was more likely after laparoscopic surgery than after open surgery (summary RR 1.43; 95% CI, 1.15 to 1.79) (Figure 4 upper panel). We had defined the MCSD as a three-percentage-point difference between groups. To aid interpretation, we calculated the overall rate of recurrence in the open repair groups, which was 2.49 percent. Multiplying a 1.79 RR by this rate yields a corresponding rate of 4.46 percent for laparoscopy. The difference between these rates is only 1.97 percent, which is less than our predefined MCSD of three percentage points. This implies that the difference between open and laparoscopy, while statistically significant, is not substantial.

Figure 4 Key Question 2: Meta-analyses of recurrence

KQ2a: I^2^=21%, tau=0.21

KQ2b: I^2^=0%, tau=0

KQ2c: I^2^=25%, tau=0.15

The figure shows the results of a meta-analysis comparing laparoscopic repair and open repair on the outcome Recurrence in the context of painful hernia in adults. Points to the left of the midline favor laparoscopic repair, whereas points to the right of the midline favor open repair. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

#### Length of Hospital Stay

Twenty-five of the 38 studies reported an outcome in this category, and 17 of these could be included in a meta-analysis of the length of stay in days (the other eight only reported dichotomous data, e.g., the percentage of patients who had a 1-day stay). The meta-analysis (Figure 5 upper panel) found that length of stay was shorter after laparoscopic surgery than after open surgery (summary difference in means -0.33 days; 95% CI, -0.52 to -0.14). This is only about an 8-hour difference (i.e., a third of a day), which is less than what we defined as the MCSD (1 day; see Methods section).

Figure 5 Key Question 2: Meta-analyses of length of stay

KQ2a: I^2^=94%, tau=0.34

KQ2b: I^2^=98%, tau=2.39

KQ2c: I^2^=98%, tau=1.38

The figure shows the results of a meta-analysis comparing laparoscopic repair and open repair on the outcome Length of Stay in the context of painful hernia in adults. Points to the left of the midline favor laparoscopic repair, whereas points to the right of the midline favor open repair. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

#### Return to Daily Activities

Nineteen of the 38 studies reported an outcome in this category, and 15 of these could be included in a meta-analysis of number of days before returning to normal daily activities. The other four could not be included because the authors only reported dichotomous data, did not report numbers of patients, reported only specific activities (such as the length of postoperative time before being able to urinate), or used a functional index scale rather than a length of time to return to activity. The meta-analysis (Figure 6 upper panel) found that RTDA was shorter after laparoscopic surgery than after open surgery (summary weighted mean difference in days of -3.9; 95% CI, -5.6 to -2.2). This is larger than what we defined as the MCSD for this outcome (1 day).

Figure 6 Key Question 2: Meta-analyses of return to activities of daily living

KQ2a: I^2^=95%, tau=3.11

KQ2b: I^2^=92%, tau=8.15

KQ2c: I^2^=0%, tau=0

The figure shows the results of a meta-analysis comparing laparoscopic repair and open repair on the outcome Return to Activities of Daily Living in the context of painful hernia in adults. Points to the left of the midline favor laparoscopic repair, whereas points to the right of the midline favor open repair. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

The meta-analysis found substantial heterogeneity and had at least 10 studies, so we performed meta-regressions in an attempt to explain differences among studies. We investigated numerous covariates (percentage of patients with bilateral hernia, percentage of patients with recurrent hernia, mean age, percentage of laparoscopic patients undergoing TEP, percentage of open patients undergoing Lichtenstein, percentage of centers in university or specialist settings, concealment of allocation, outcome rater blinded), but none of them were statistically significantly associated with the difference between open and laparoscopic repair. Despite differences in the measured size of the effect, the overall direction of the effect consistently favored laparoscopy.

#### Return to Work

Twenty of 38 studies reported RTW data, and 19 of them were combined in a meta-analysis (the other did not report the Ns). The meta-analysis (Figure 7 upper panel) indicated shorter time to RTW after laparoscopic repair (summary difference in days -4.6 days; 95% CI, -6.1 to -3.1). This is larger than what we defined as the MCSD for this outcome (1 day).

Figure 7 Key Question 2: Meta-analyses of return to work

KQ2a: I^2^=88%, tau=2.93

KQ2c: I^2^=81%, tau=4.39

The figure shows the results of a meta-analysis comparing laparoscopic repair and open repair on the outcome Return to Work in the context of painful hernia in adults. Points to the left of the midline favor laparoscopic repair, whereas points to the right of the midline favor open repair. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

The meta-analysis found substantial heterogeneity and had at least 10 studies, so we performed meta-regressions in an attempt to explain differences among studies. We investigated numerous covariates (percentage of patients with bilateral hernia, percentage of patients with recurrent hernia, mean age, percentage of laparoscopic patients undergoing TEP, percentage of open patients undergoing Lichtenstein, percentage of centers in university or specialist settings, concealment of allocation, similar levels of prior surgical experience, outcome rater blinded), but none of them were statistically significantly associated with the difference between open and laparoscopic repair. Despite differences in the measured size of the effect, the overall direction of the effect consistently favored laparoscopy.

#### Quality of Life

Only one study reported long-term QOL data, and results suggested equivalence (on the 0-1 scale of Quality Adjusted Life Years [QALYs], the 2-year difference in QALYs was only 0.014; 95% CI, -0.014 to 0.041).

#### Patient Satisfaction

Three studies reported long-term data on this outcome, but they each reported it in a different way:

- One study reported degree of SFN on a VAS 0–100 scale, with medians of 100 for the laparoscopic group and 98 for the open group. This was reported as not statistically significantly different, but a CI was neither reported nor calculable, so it is unclear whether the results indicate equivalence.
- A second study reported the percentages of patients who were “completely satisfied”/“satisfied”/“unsatisfied” (91/7/1 for the laparoscopic group versus 75/20/5 for the open group). The study also reported the percentage of patients who said they would have this procedure again, which was 98 percent for the laparoscopic group versus 86 percent for the open group. The study did not perform statistical tests on these outcomes, but we did (chi square tests), and both measures showed statistically significantly greater SFN in the laparoscopic group.
- A third study asked four pertinent questions: (1) whether recovery was faster than expected, 59 percent laparoscopy patients versus 45 percent open patients; (2) SFN with operation scars, 82 percent laparoscopy patients versus 71 percent open patients; (3) whether they would recommend that operation to others, 91 percent laparoscopy patients versus 91 percent open patients; and (4) whether they could describe life as “much better,” 62 percent laparoscopy patients versus 61 percent open patients. Authors did not report any statistical tests on these data, but our tests found that one of the four measures, SFN with operation scars, showed a statistically significant difference (82 percent vs. 71 percent), whereas the others were not statistically significant.

#### Long-Term Pain

All but one of 14 studies reporting long-term pain (>6 months after surgery) were included in a meta-analysis (Figure 8 upper panel) (the 14^th^ study did not report data dichotomously). This analysis found a lower rate of long-term pain after laparoscopic surgery than after open surgery (OR=0.61; 95% CI, 0.48 to 0.78). This indicates a clinically significant difference in rates.

Figure 8 Key Question 2: Meta-analyses of long-term pain

KQ2a: I^2^=39%, tau=0.25

KQ2c: I^2^=0%, tau=0

The figure shows the results of a meta-analysis comparing laparoscopic repair and open repair on the outcome Long-Term Pain in the context of painful hernia in adults. Points to the left of the midline favor laparoscopic repair, whereas points to the right of the midline favor open repair. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

The meta-analysis found substantial heterogeneity and had at least 10 studies, so we performed meta-regressions in an attempt to explain differences among studies. We investigated numerous covariates (percentage of patients with bilateral hernia, percentage of patients with recurrent hernia, mean age, percentage of laparoscopic patients undergoing TEP, percentage of open patients undergoing Lichtenstein, percentage of centers in university or specialist settings, concealment of allocation, similar levels of prior surgical experience, length of followup), but none of them were statistically significantly with regard to the difference between open and laparoscopic repair. Despite differences in the measured size of the effect, the overall direction of the effect consistently favored laparoscopy.

The severity of the pain may not have differed substantially between treatments. Two of the 14 studies measured the degree of pain severity in the long term. One study found that at 2 years, the between-group difference in pain at rest was no more than 3.5 millimeters, which corresponds to only 2.3 percent of the 150-millimeter scale range. The other study reported pain severity at both 6 months and 1 year: patients receiving laparoscopy had less pain severity, and the difference was about 0.7 points on a 0–10 scale (7 percent of the scale range).

#### Adverse Events

We conducted meta-analyses of six types of events (epigastric vessel injury reported by 10 studies [Figure 9 upper panel], hematoma reported by 25 studies [Figure 10 upper panel], small bowel injury reported by four studies [Figure 11], small bowel obstruction reported by seven studies [Figure 12], urinary retention reported by 20 studies [Figure 13 upper panel], and wound infection reported by 18 studies [Figure 14 upper panel]). A clear direction of effect was found for three events: epigastric vessel injury (higher rates with laparoscopic repair, OR=2.1; 95% CI, 1.1 to 3.9), hematoma (lower rates with laparoscopic repair, OR=0.70; 95% CI, 0.55 to 0.88), and wound infection (lower rates with laparoscopic repair, OR=0.49; 95% CI, 0.33 to 0.71). For the other three events, the evidence was inconclusive because it was consistent with effects in either direction.

Figure 9 Key Question 2: Meta-analyses of epigastric vessel injury

KQ2a: I^2^=9%, tau=0.30

KQ2c: I^2^=7%, tau=0.4

The figure shows the results of a meta-analysis comparing laparoscopic repair and open repair on the outcome Epigastric Vessel Injury in the context of painful hernia in adults. Points to the left of the midline favor laparoscopic repair, whereas points to the right of the midline favor open repair. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

Figure 10 Key Question 2: Meta-analyses of hematoma

KQ2a: I^2^=7%, tau=0.14

KQ2b: I^2^=0%, tau=0

The figure shows the results of a meta-analysis comparing laparoscopic repair and open repair on the outcome Hematoma in the context of painful hernia in adults. Points to the left of the midline favor laparoscopic repair, whereas points to the right of the midline favor open repair. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

Figure 11 Key Question 2: Meta-analysis of small bowel injury

KQ2a: I^2^=0%, tau=0

The figure shows the results of a meta-analysis comparing laparoscopic repair and open repair on the outcome Small Bowel Injury in the context of painful hernia in adults. Points to the left of the midline favor laparoscopic repair, whereas points to the right of the midline favor open repair. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

Figure 12 Key Question 2: Meta-analysis of small bowel obstruction

KQ2a: I^2^=0%, tau=0

The figure shows the results of a meta-analysis comparing laparoscopic repair and open repair on the outcome Small Bowel Obstruction in the context of painful hernia in adults. Points to the left of the midline favor laparoscopic repair, whereas points to the right of the midline favor open repair. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

Figure 13 Key Question 2: Meta-analyses of urinary retention

KQ2a: I^2^=31%, tau=0.45

KQ2b: I^2^=74%, tau=2.61

KQ2c: I^2^=0%, tau=0

The figure shows the results of a meta-analysis comparing Lichtenstein and mesh plug on the outcome Urinary Retention in the context of painful hernia in adults. Points to the left of the midline favor Lichtenstein, whereas points to the right of the midline favor mesh plug. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

Figure 14 Key Question 2: Meta-analyses of wound infection

KQ2a: I^2^=0%, tau=0

KQ2b: I^2^=0%, tau=0

KQ2c: I^2^=0%, tau=0

The figure shows the results of a meta-analysis comparing Lichtenstein and mesh plug on the outcome Wound Infection in the context of painful hernia in adults. Points to the left of the midline favor Lichtenstein, whereas points to the right of the midline favor mesh plug. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

For urinary retention, the meta-analysis found substantial heterogeneity and had at least 10 studies, so we performed meta-regressions in an attempt to explain differences among studies. We investigated numerous covariates (percentage of patients with bilateral hernia, percentage of patients with recurrent hernia, mean age, percentage of laparoscopic patients undergoing TEP, percentage of open patients undergoing Lichtenstein, percentage of centers in university or specialist settings, concealment of allocation, similar levels of prior surgical experience, outcome rater blinded), but none of them were statistically significantly associated with the difference between open and laparoscopic repair.

Another adverse event of concern is intraoperative injury to the spermatic cord (potentially causing infertility). Only two studies reported data on this event. In one study, the event never occurred (out of 67 patients undergoing open repair and 122 undergoing laparoscopic repair). In the other study, the rates were 1% after open repair (8/994) and 0.1% after laparoscopic repair (1/989).

### Applicability

Thirty-seven studies are included for review for Key Question 2a. We evaluated these studies to identify factors that could potentially affect the applicability of the evidence. As described in the Methods section, the goal of the evaluation is to draw stakeholders' attention to potential applicability issues embedded in the evidence rather than generating a rating or score for the applicability.

The thirty-seven studies reviewed for Key Question 2a compared various mesh-based open surgeries with laparoscopic procedures. Table 11 in Appendix C provides a detailed description of the procedures being compared in the studies. The two interventions being compared in the meta-analyses—i.e., open versus laparoscopic surgery—included different procedures (e.g., the Lichtenstein method, the mesh plug method, TEP, and TAPP). The findings from the meta-analyses (e.g., effect sizes) might not apply to comparisons of specific procedures (e.g., the Lichtenstein method vs. TEP or the mesh plug method vs. TEP). Meanwhile, in 34 of the 37 studies reviewed for Key Question 2a, the surgeries were performed in the 1990s or early 2000s. This body of evidence may not necessarily reflect the comparative performance of the procedures that are performed currently.

Twenty-one of the 37 studies reviewed for Key Question 2a provided information on surgeons' prior experience for the surgeries being compared.17,36,37,53-96 Surgeons' level of experience was reported as “experienced,” “highly experienced,” “with moderate experience,” or by the number of prior cases. When the term “experienced” was used, the meaning of the term was rarely defined (e.g., by the number of prior cases or years of practice). Sixteen of the 37 studies reviewed did not report data on surgeons' experience at all. Given the limitation in data reported, we were unable to judge what implication surgeons' experience may have in the applicability of the evidence. Table 15 in Appendix C provides additional detail on the hernia repair procedures performed in the studies, including data on surgeons' experiences.

Patient enrollment criteria and reported baseline characteristics varied significantly across the 37 studies. Almost half of the studies reviewed excluded female patients or patients unfit for general anesthesia. Some studies excluded patients with bilateral or incarcerated hernia. Based on the data reported, we did not identify any clear patterns in the patient characteristics of the studies that indicate significant impact on the applicability of the evidence. Detailed patient enrollment criteria and baseline characteristics of these studies are provided in Appendix C in Table 12 and Table 13.

Except for three studies,36,57,83-88,90 all of the other 34 studies were performed outside of the United States, primarily in European countries. The differences in health care systems and practice patterns between the United States and Europe might have an impact on the applicability of the evidence from the perspectives of U.S. stakeholders. The clinical settings where the 37 studies were conducted varied significantly, ranging from outpatient surgical clinics to community hospitals to academic medical centers. Based on the data reported, it is unclear how the clinical settings of the studies might affect the applicability of the evidence. Detailed information on geographic and clinical settings of the 37 studies is provided in Appendix C in Table 11.

### Summary of Key Question 2a

A summary of the comparisons and outcomes we examined in this Key Question is in Table 4 below. Of the 11 outcomes, the evidence was sufficient to permit a conclusion for eight outcomes:

- Five outcomes favored laparoscopy (RTDA, RTW, long-term pain, hematoma, and wound infection)
- Two outcomes favored open surgery (r and epigastric vessel injury)
- One outcome indicated approximate equivalence (length of stay)

Table 4 Key Question 2a: Strength of evidence ratings

Comparison | Outcome | # Studies | Overall Risk of Bias | Consistency | Directness | Precision | Evidence Favors | SOE Rating
Lap. vs. open | Hernia recurrence | 30 | MOD | I | D | P RR 1.43 (CI 1.2 to 1.8) | Open | LOW
Lap. vs. open | Length of stay (days) | 25 | MOD | I | D | P Diff. -0.33 (CI -0.52 to -0.14) | EQ | LOW
Lap. vs. open | RTDA (days) | 19 | MOD | C | D | P Diff. 3.9 days (CI 2.2 to 5.6) | Lap. | HIGH^*^
Lap. vs. open | RTW (days) | 20 | MOD | C | D | P Diff. 4.6 days (CI 3.1 to 6.1) | Lap. | HIGH^*^
Lap. vs. open | Quality of life (QALYs) | 1 | MOD | U | D | P (QALY difference -0.0135 to 0.0405) | ? | INSUFF^†^
Lap. vs. open | Patient satisfaction | 3 | MOD | I | D | I (CI not calculable) | ? | INSUFF^†^
Lap. vs. open | Long-term pain (% of patients) | 14 | MOD | C | D | P OR 0.61 (CI 0.48 to 78) | Lap. | MOD
Lap. vs. open | Epigastric vessel injury | 9 | MOD | C | D | P OR 2.1 (CI 1.1 to 3.9) | Open | LOW^†^
Lap. vs. open | Hematoma | 25 | MOD | I | D | P OR 0.70 (CI 0.55 to 88) | Lap. | LOW
Lap. vs. open | Small bowel injury | 4 | MOD | I | D | I (OR 0.11 to 4.6) | ? | INSUFF^†^
Lap. vs. open | Small bowel obstruction | 7 | MOD | C | D | I (OR 0.58 to 8.0) | ? | INSUFF^†^
Lap. vs. open | Urinary retention | 20 | MOD | I | D | I (OR 0.84 to 1.86) | ? | INSUFF
Lap. vs. open | Wound infection | 18 | MOD | C | D | P OR 0.49 (CI 0.33 to 71) | Lap. | MOD

CI = confidence interval, NA = not applicable, OR = odds ratio, QALY = quality-adjusted life year; RR = relative risk, RTDA = return to activities of daily living, RTW = return to work.

Note:

For risk of bias, MOD. = Moderate.

For consistency, C = consistent, I = inconsistent, U = unknown consistency because there was only one study.

For directness, D = direct, I = indirect.

For precision, I = imprecise, P = precise.

For the column labeled “Evidence favors,” ? denotes inconclusive evidence, and EQ denotes approximate equivalence.

For the column labeled SOE rating, INSUFF = insufficient,

* indicates that the SOE was upgraded due to a large magnitude of effect. SOE = strength of evidence, and

† indicates that the SOE was downgraded due to publication bias or selective outcome reporting.

Our ratings of the SOE for these outcomes also appear in the table. Studies were typically at moderate risk of bias (see the pertinent section above); we found some inconsistencies for some outcomes based on effect sizes on opposite sides of a null effect; all of these outcomes are directly important to clinicians and patients; we found some imprecision for some outcomes that precluded conclusions. Two outcomes were judged to have a large magnitude of effect (RTDA and RTW, both of which indicated advantages of laparoscopy in excess of 2 days and possibly as much as 6 days). Three of the adverse events were judged to potentially be associated with publication bias, specifically in the form of selective outcome reporting (for example, only 4 of 37 studies reported rates of small bowel injury, and the authors' choice to report that data may have been influenced by the nature of the findings).

For the outcome of hernia recurrence, we concluded that evidence favors open repair (based on a meta-analysis of 30 studies) in the context of primary hernia. A key concern is timing: for how long does this advantage occur? This is difficult to pinpoint because studies differed in the length of followup. The median length of followup was 1.4 years (range 10 months to 7.3 years). Three studies followed the typical patient for <1 year, 17 studies followed the typical patient for 1-2 years, and the remaining 10 studies followed the typical patient for 2+ years.

Questions about the relative importance of these outcomes need to be considered carefully. Some may believe the advantages of laparoscopic repair (faster recovery and lower rates of minor complications) may outweigh the disadvantages (higher rates of recurrence and epigastric vessel injury), whereas others may believe that its disadvantages outweigh the advantages.

Nine non-English studies might have met the inclusion criteria for this Key Question if we had not required that studies be published in English.97-105 Three of these were clearly randomized trials, and the other six may have been randomized (the abstract was unclear on this point).We summarize the results as follows:

- One RCT100 (comparing laparoscopic intraperitoneal onlay mesh (IPOM) with open mesh plug) found lower rates of hematoma, wound infection, and short-term pain after IPOM, as well as faster recovery after IPOM.
- Another RCT98 (comparing TAPP with Lichtenstein) did not find faster recovery or less pain after TAPP, and also did not find lower rates of hematoma after TAPP. These results are not consistent with the conclusions of our review. No recurrences were observed, but authors did find three contralateral hernias during TAPP and no such hernias during Lichtenstein.
- A third RCT99 (comparing TAPP with “open mesh herniorrhaphy”) found shorter hospital stay and RTDA after TAPP, and no difference in overall complication rates (specific complications were not delineated in the abstract of the study). Overall consistency with our review is unclear. No RCs were observed in the 1-year followup period.
- One study97 (possibly randomized, comparing TEP to Lichtenstein) found higher complication rates in the TEP group, and no TEP advantages regarding patient SFN. Specific complications were not reported in the abstract, so consistency with our review is unclear.
- One study101 (possibly randomized, comparing TEP to Lichtenstein) found that TEP patients had faster recovery and lower rates of long term pain (consistent with our findings), and found no differences in recurrence or complication rates.
- One study102 (possibly randomized, comparing TEP to “open tension free operation (OTF) using the onlay flat mesh technique”) found less short-term pain after TEP.
- One study103 (possibly randomized, comparing “laparoscopic surgery (intraabdominal preperitoneal repair)” to “open surgery (tension free repair)” only reported short-term surrogate outcomes such as fasting plasma glucose and C-reactive protein, which were not outcomes of interest in our review.
- One study105 (possibly randomized, comparing “laparoscopic approach” to a set of open procedures [“Bassini, Shouldice, Lichtenstein”]) found laparoscopic advantages regarding “shorter hospitalization, lower morbidity and rapid socioprofessional reintegration.” Consistency with our review is mixed.
- One study106 (possibly randomized, comparing TEP to Stoppa) found 1-year recurrence rates of 2.2 percent and 0 percent (respectively), 3-year recurrence rates of 3.6 percent and 5.2 percent (respectively), and 4-year recurrence rates of 7.4 percent and 10.5 percent (respectively). The longer term rates, which favor laparoscopy, are opposite of our review's findings that long-term recurrence rates favor open surgery for primary hernia.

## Key Question 2b Does open hernia repair with a mesh differ from laparoscopic hernia repair with a mesh in patient-oriented effectiveness outcomes and/or adverse events? Bilateral hernias

### Study Characteristics

General information about the six studies included for this Key Question appears in Table 19 of Appendix C. Each was conducted in a different country (Denmark, France, Italy, Switzerland, Turkey, and the United Kingdom). Three were single-center randomized trials, one was a two-center RCT, one was an RCT that did not report the number of centers, and the last was the Danish registry that was also included for Key Question 2a. Three studies compared TEP to the Stoppa procedure, two compared TAPP to Lichtenstein, and the Danish registry compared TAPP/TEP to Lichtenstein (authors combined data on TAPP and TEP procedures). Three of these six studies were also included for Key Question 2a on primary hernia; they were included for this question also because they reported subgroup analyses specifically for those with bilateral hernia.

Patient enrollment in the RCTs ranged from 43 to 403, and patients were enrolled in the same timeframe as the studies included for Key Question 2a (the mid-1990s to early 2000s). Four of the five RCTs were conducted in university hospitals (the fifth did not report the type of hospital). Funding source was unreported in three of the six studies; two involved government funding, and one RCT was supported by a manufacturer (Ethicon Endo-Surgery, Inc., a unit of Johnson & Johnson, New Brunswick, NJ). Patient enrollment criteria appear in Appendix C in Table 20 (hernia-related criteria), Table 21 (demographic and medical criteria), and Table 22 (other criteria). Generally, their criteria were similar to the studies included for Key Question 2a, with the obvious exception that no studies excluded bilateral hernia. Three studies excluded giant scrotal hernia, two excluded femoral hernia, two excluded incarcerated hernia, and one excluded RC. Four included any adults, whereas the other two set more specific age boundaries. Five excluded those unfit for general anesthesia, and three excluded those with prior lower abdominal surgery; only one specifically excluded women.

Treatment details appear in Table 23 of Appendix C. For laparoscopic repair, three studies performed TAPP and three performed TEP; either procedure typically involved general anesthesia. Meshes were typically stapled, and for bilateral hernias, two studies used two meshes in each patients (one on each side), one used a single large (30 by 10 cm) “bikini” mesh, one reported that either one large or two regular-sized meshes were used, and two studies did not report information about meshes. The open procedure was Lichtenstein in three studies and Stoppa in three studies; the Stoppa procedure involves a single large mesh to cover both hernia defects.

Baseline patient characteristics appear in Table 24 of Appendix C, and these were similar to patients included for Key Question 2a (other than the fact that Key Question 2b patients had bilateral hernia). See the pertinent section in Key Question 2a for an overview.

### Risk of Bias

Our risk-of-bias assessments for the six studies appear in Table 25 of Appendix C. The five RCTs were all categorized as Moderate risk of bias for all of their outcomes, and the Danish registry study was categorized as High risk of bias. The reasons for this latter category assignment were mentioned above in Key Question 2a (nonrandom assignment, retrospectivity, lack of concealment of allocation, outcomes assessed with knowledge of treatment, and potential selection bias). Reasons for assigning a Moderate category to the five RCTs were the same as those discussed in Key Question 2a: possible differences in prior surgical expertise, lack of concealment of allocation (either not done or not reported in three of six studies), and lack of outcome assessor blinding (clearly not done in two studies, and unreported in the other four studies).

### Findings

All included data for this Key Question appear in Table 26 of Appendix C.

#### Hernia Recurrence

We performed a meta-analysis of all three studies reporting this outcome specifically for bilateral hernia, and found that the evidence was inconclusive (summary RR 1.07; 95% CI, 0.19 to 6.06) (Figure 4 middle panel). This is inconclusive because the evidence is simultaneously consistent with a large advantage of laparoscopy (recurrence one-fifth as likely with laparoscopy) but also with a large advantage of open repair (recurrence six times as likely with laparoscopy). The length of followup was 1 year in two studies, and a range from 0–3 years in the third study.

#### Length of Hospital Stay

Four of the six studies reported an outcome in this category, and all of them could be included in a meta-analysis (Figure 5 middle panel). This meta-analysis was inconclusive (summary weighted mean difference in days -1.7; 95% CI, -4.1 to +0.6).

#### Return to Daily Activities

Both studies reporting RTDA were meta-analyzed, but the resulting estimate was too variable to be conclusive (summary difference in days -9.0; 95% CI, -20.7 to +2.8) (Figure 6 middle panel).

#### Return to Work

Only one of the six studies reported data on RTW, and the authors reported a much shorter RTW after laparoscopy (median 16 days) than after open surgery (median 30 days; (p <0.05).

#### Quality of Life

None of the studies reported QOL data.

#### Patient Satisfaction

None of the studies reported patient SFN data.

#### Long-Term Pain

None of the studies reported long-term pain data.

#### Adverse Events

Of the six adverse events we considered major outcomes (see list in Methods section), only three were reported by any of the six studies (hematoma, urinary retention, and wound infection, each reported by two studies). We conducted meta-analyses of these three events, (middle panels of Figure 10, Figure 13, and Figure 14, respectively), but for all three the evidence was inconclusive because it was consistent with effects in either direction.

### Applicability

Six studies are included for review for Key Question 2b. We evaluated these studies to identify factors that might affect the applicability of the evidence. As described in the Methods section, the goal of the evaluation is to raise stakeholders' awareness of potential applicability issues embedded in the evidence rather than to generate a rating or score for the applicability.

These six studies reviewed for Key Question 2b compared two mesh-based open surgeries—the Stoppa and the Lichtenstein methods—with two laparoscopic procedures— TAPP and TEP— for repairing bilateral hernias. Table 23 of Appendix C provides a detailed description of the procedures being compared in the studies. The two interventions being compared in the meta-analyses—i.e., open versus laparoscopic surgery—included all four different procedures. The findings of the meta-analyses (e.g., effect sizes) might not apply to comparisons of specific procedures (e.g., the Lichtenstein method vs. TAPP, or the Stoppa method vs. TEP). Meanwhile, in one of the four studies, the surgeries were performed between 2003 and 2007.^107^ In the other five studies, the surgeries were performed in the 1990s. This body of evidence may not necessarily reflect the comparative performance of the procedures that are performed currently.

One of the six studies reviewed for Key Question 2b provided information on surgeons' prior experience for the surgeries being studied.58-61 This study reported that the surgeon had a prior experience of 50 cases with TEP. Another study reported the annual numbers of cases performed by hospital departments.24,108-112 The other four studies reviewed did not report data on the surgeons' level of experience. Given limited data, we were unable to judge what implication surgeons' experience may have in the applicability of the evidence. Table 23 of Appendix C provides additional detail on the hernia repair procedures performed in the studies, including any available data on surgeons' experience.

Patient enrollment criteria and reported baseline characteristics varied significantly across the six studies. For example, some studies excluded patients with prior lower abdominal surgeries, while others studies excluded patients unfit for general anesthesia. Based on the data reported, we did not identify any clear patterns in the patient characteristics of the studies that indicate significant impact on the applicability of the evidence. Detailed patient enrollment criteria and baseline characteristics of these studies are provided in Appendix C.

All six studies were performed outside of the United States, primarily in European countries. The differences in health care systems and practice patterns between the United States and Europe might have impact on the applicability of the evidence from the perspectives of U.S. stakeholders. Four of the five RCTs were conducted in university hospitals (the fifth did not report the type of hospital). The only non-RCT study involved 76 centers in Denmark and reported that 76 percent of the surgeries were performed in hospital departments and the other 24 percent occurred in private clinics. Based on the data reported, it is unclear how the clinical settings of the studies might affect the applicability of the evidence. Detailed information on geographic and clinical settings of the six studies is provided in Appendix C in Table 19.

### Summary of Key Question 2b

A summary of the comparisons and outcomes we examined in this Key Question is in Table 5 below. The evidence was sufficient to permit conclusions for only one outcome: that bilateral hernia patients return to work sooner if they receive laparoscopic repair. This was rated as Low SOE because only one of the six included studies reported information on return to work (therefore consistency with other studies could not be determined). This outcome had also been upgraded for a large magnitude of effect, but also was downgraded for potential reporting bias. For other outcomes, the primary reason for the grade of Insufficient was a lack of precision. For example, for RC, the direction of the effect could favor laparoscopy with an OR of about 0.2, or it could favor open surgery with an OR of more than 6. The outcomes downgraded for potential reporting bias included return to activities of daily living, hematoma, urinary retention, and wound infection.

Table 5 Key Question 2b: Strength of evidence ratings

Comparison | Outcome | # Studies | Overall Risk of Bias | Consistency | Directness | Precision | Evidence Favors | SOE Rating
Lap. vs. open | Hernia recurrence | 3 | MOD. | I | D | I (RR 0.19 to 6.06) | ? | INSUFF
Lap. vs. open | Length of stay (days) | 4 | MOD. | C | D | I (Diff in days -4.1 to +0.6) | ? | INSUFF
Lap. vs. open | RTDA (days) | 2 | MOD. | C | D | I (Diff in days -20.7 to +2.8) | ? | INSUFF^†^
Lap. vs. open | RTW (days) | 1 | MOD. | U | D | P 14 days earlier (CI not reported, but p <0.05) | Lap. | LOW^*,†^
Lap. vs. open | Hematoma | 2 | MOD. | I | D | I (OR 0.074 to 2.56) | ? | INSUFF^†^
Lap. vs. open | Urinary retention | 2 | MOD. | I | D | I (OR 0.017 to 73.2) | ? | INSUFF^†^
Lap. vs. open | Wound infection | 2 | MOD. | C | D | I (OR 0.019 to 1.41) | ? | INSUFF^†^

CI = Confidence interval; NA = not applicable, OR = odds ratio, RR = relative risk; RTDA = return to activities of daily living; RTW = return to work.

Note:

For risk of bias, MOD. = Moderate.

For consistency, C = consistent, I = inconsistent, U = unknown consistency because there was only one study.

For directness, D = direct, I = indirect.

For precision, P = precise, I = imprecise.

For the column labeled “Evidence favors,” ? denotes inconclusive evidence, and EQ denotes approximate equivalence. SOE = strength of evidence.

For the column labeled SOE rating, INSUFF = insufficient,

* indicates that the SOE was upgraded due to a large magnitude of effect, and

† indicates that the SOE was downgraded due to publication bias or selective outcome reporting.

One excluded non-English article compared open and laparoscopic repair for bilateral hernia.104 The specific comparison was TEP versus Stoppa, and the abstract gave conflicting statements about whether patients were randomly assigned to groups. Because the numbers of patients in the two groups were quite different (43 and 74), it seems unlikely that random assignment was used. Given the possibility of selection bias (assuming the authors employed no analytic controls such as propensity scores), the article would not have met our inclusion criteria for this question.

## Key Question 2c Does open hernia repair with a mesh differ from laparoscopic hernia repair with a mesh in patient-oriented effectiveness outcomes and/or adverse events? Recurrent hernias

### Study Characteristics

General information about the eight studies included for this Key Question appears in Table 27 of Appendix C. Two were from Sweden, and the others were from six different countries (Denmark, Finland, France, Greece, the Netherlands, and the United States). Four were single-center RCTs, two were multicenter RCTs, and two were registry studies (Denmark and Sweden, the same registries mentioned under Key Question 2a). The open mesh procedure was Lichtenstein in six studies and the Stoppa procedure in the other two studies. For the laparoscopic mesh procedure, two studies performed TAPP, two performed TEP, one performed both and reported data separately, and the other three performed both TAPP and TEP and combined the data. Four of these eight studies were also included for Key Question 2a on primary hernia; they were included for this question also because they reported subgroup analyses specifically for those with RC.

The six RCTs enrolled between 43 and 184 patients with recurrent inguinal hernia. Patients were enrolled in the same timeframe as the studies included for Key Question 2a (the mid-1990s to early 2000s). Four studies were conducted at general and nonuniversity hospitals, two were conducted at university hospitals, and two included some university hospitals as well as some nonuniversity hospitals. Five studies mentioned funding source: three were government-funded, one was hospital-funded, and one was partially funded by a manufacturer that was not involved in study design and analysis.

Patient enrollment criteria appear in Table 28 (hernia-related criteria), Table 29 (demographic and medical criteria), and Table 30 (other criteria) of Appendix C. Two studies excluded bilateral hernia, two excluded strangulated hernia, two excluded incarcerated hernia, and two excluded giant scrotal hernia (some studies excluded one or more of these hernia types). Four included any adults, whereas the other four set more specific age boundaries. Five excluded those unfit for general anesthesia, three excluded those with prior lower abdominal surgery, three excluded those whose prior hernia operation employed a mesh, three specifically excluded women, and three excluded patients with coagulation disorders.

Treatment details appear in Table 31 of Appendix C. For laparoscopic repair, four studies used both TAPP and TEP, two exclusively performed TAPP, and two exclusively performed TEP. As in previous Key Questions, general anesthesia and mesh stapling were the norm, and a variety of mesh sizes were used. For open repair, six studies used Lichtenstein and two performed Stoppa repairs.

Baseline patient characteristics appear in Table 32 of Appendix C, and these were similar to patients included for Key Question 2a (other than the fact that Key Question 2c patients had recurrent hernia). See the pertinent section in Key Question 2a for an overview.

### Risk of Bias

Our risk-of-bias assessments for the eight studies appear in Table 33 of Appendix C. The six RCTs were all categorized as Moderate risk of bias for all of their outcomes, and the two registry studies was categorized as High risk of bias. The reasons for these latter category assignments were mentioned above in Key Question 2a (nonrandom assignment, retrospectivity, lack of concealment of allocation, outcomes assessed with knowledge of treatment, and potential selection bias). Reasons for assigning a Moderate category to the six RCTs were the same as those discussed in Key Question 2a: possible differences in prior surgical expertise, lack of concealment of allocation (either not done or not reported in two of six RCTs), and lack of outcome assessor blinding (clearly not done in one RCT, and unreported in three other RCTs).

### Findings

All included data for this Key Question appear in Table 34 of Appendix C.

#### Hernia Recurrence

Given that this question addresses patients who are undergoing surgery for RC, this outcome is technically hernia re-recurrence. Seven of the eight studies reported data on this outcome. A meta-analysis of these data favored laparoscopic repair over open repair (summary RR 0.76; 95% CI, 0.60 to 0.98) (Figure 4 lower panel). The length of followup varied widely across the studies, with one study following patients from 0–3 years and another followed patients for an average of 5.3 years. As with Key Question 2a on primary hernia, we had defined the MCSD for RC as three percentage points. To aid interpretation of the summary RR of 0.76, we calculated the overall rate of re-recurrence in the open repair groups, which was 12.5 percent. Applying an RR of 0.76 to this rate yields a laparoscopic re-recurrence rate of 9.5 percent; applying it to the lower bound of RR 0.60 yields a lower percentage of 7.5 percent; applying it to the upper bound of RR=0.98 yields an upper bound of 12.3 percent. Thus the difference in percentages could be as high as 4.8 percent (12.3 percent to 7.5 percent), which is higher than our MCSD of three percentage points. Thus, it is unclear whether the advantage of laparoscopy for preventing re-recurrence can be considered clinically significant.

#### Length of Hospital Stay

Five of the eight studies reported an outcome in length of hospital stay, and three of these could be included in a meta-analysis (Figure 5 lower panel) (the other two reported the length-of-stay data only dichotomously). This meta-analysis was inconclusive (summary weighted mean difference=-1.3 days; 95% CI, -2.8 to +0.33).

#### Return to Daily Activities

Two of three studies reporting RTDA were meta-analyzed (the third used a functional index scale instead of reporting the amount of time). The meta-analysis (Figure 6 lower panel) indicated an advantage of laparoscopic repair (summary weighted mean difference in days=-7.4 days; 95% CI, -11.4 to -3.4).

#### Return to Work

Two of three studies reporting RTW were meta-analyzed (the third did not report the Ns). The meta-analysis (Figure 7 lower panel) did not indicate a clear direction of effect (summary weighted mean difference -6.4 days; 95% CI, -13.2 to +0.34).

#### Quality of Life

None of the studies reported QOL data.

#### Patient Satisfaction

None of the studies reported SFN data.

#### Long-Term Pain

Three studies reported long-term pain data, and two were meta-analyzed (Figure 8 lower panel) (the third did not report the Ns). This meta-analysis indicated lower rates of long-term pain after laparoscopy (OR=0.24; 95% CI, 0.08 to 0.74). This indicates a clinically significant difference in rates. The severity of pain is unclear, however, because none of the three studies measured long-term pain on a continuous scale.

#### Adverse Events

Of the six adverse events we considered major outcomes (see list in Methods section), four were reported by any of the six studies (epigastric vessel injury reported by two studies, hematoma reported by one study, urinary retention reported by three studies, and wound infection reported by three studies). We conducted meta-analyses of these four events (lower panels of Figure 9, Figure 10, Figure 13, and Figure 14, respectively), but for all four the evidence was inconclusive because it was consistent with effects in either direction.

### Applicability

Eight studies are included for review for Key Question 2c. We evaluated these studies to identify factors that might affect the applicability of the evidence. As described in the Methods section, the goal of the evaluation is to raise stakeholders' attention to potential applicability issues embedded in the evidence rather than generating a rating or score for the applicability.

The eight studies reviewed for Key Question 2c compared mesh-based open surgeries including the Stoppa and the Lichtenstein methods with laparoscopic procedures including TAPP and TEP for repairing recurrent hernias. Table 27 of Appendix C provides a detailed description of the procedures being compared in the studies. The two interventions being compared in the meta-analyses—i.e., open versus laparoscopic surgery—included different procedures (e.g., the Lichtenstein and Stoppa methods, TEP, and TAPP). The findings from the meta-analyses (e.g., effect sizes) might not apply to comparisons of specific procedures (e.g., the Lichtenstein method vs. TEP, or the mesh plug method vs. TEP). Meanwhile, in eight studies reviewed for Key Question 2c, the surgeries were performed in the 1990s or early 2000s. This body of evidence may not necessarily reflect the comparative performance of the procedures that are performed currently.

Five of the eight studies reviewed for Key Question 2c discussed surgeons' prior experience for the surgeries being compared.23,24,36,58-61,83-88,108-113 The surgeons in the studies include experts with “special training,” residents, or those having more than 25 or 50 prior cases. Three studies reviewed did not discuss surgeons' prior experiences. Given the data reported, we were unable to judge what implication surgeons' experience may have in the applicability of the overall evidence. Table 31 of Appendix C provides additional detail on the hernia repair procedures performed in the studies, including data on surgeons' experiences.

Patient enrollment criteria and reported baseline characteristics varied significantly across the eight studies. For example, some studies excluded patients with an American Society of Anesthesiologists (ASA) score >3 or patients with prior lower abdominal surgeries. Some other studies excluded patients unfit for general anesthesia. Based on the data reported, we did not identify any clear patterns in the patient characteristics of the studies that indicate significant impact on the applicability of the evidence. Detailed patient enrollment criteria and baseline characteristics of these studies are provided in Table 28 and Table 29 of Appendix C.

Except for one study,36,83-88 all other seven studies were performed outside of the United States—all in European countries. The differences in health care systems and practice patterns between the United States and Europe might have an impact on the applicability of the evidence from the perspectives of U.S. stakeholders. The clinical settings where the eight studies were conducted varied significantly, ranging from general surgery clinics, to non-teaching hospitals, to university hospitals. Based on the data reported, it is unclear how the clinical settings of the studies might affect the applicability of the evidence. Detailed information on geographic and clinical settings of the eight studies is provided in Appendix C in Table 27.

### Summary of Key Question 2c

A summary of the comparisons and outcomes we examined in this Key Question is in Table 6 below. The evidence permitted conclusions for three outcomes, all of which favored laparoscopic repair over open repair: RC (lower rates after laparoscopy), RTDA (faster after laparoscopy; evidence graded up to High due to a large effect), and long-term pain (lower rates after laparoscopy). Two outcomes (epigastric vessel injury and hematoma) had been downgraded due to potential reporting bias. This section contains no discussion of excluded non-English articles because none of those abstracts addressed recurrent hernia for open versus laparoscopic repair.

Table 6 Key Question 2c: Strength of evidence ratings

Comparison | Outcome | # Studies | Overall Risk of Bias | Consistency | Directness | Precision | Evidence Favors | SOE Rating
Lap. vs. open | Hernia recurrence | 7 | MOD. | I | D | P RR 0.82 (CI 0.70 to 0.96) | Lap. | LOW
Lap. vs. open | Length of stay (days) | 5 | MOD. | C | D | I (Diff. in days, CI -2.8 to +0.33) | ? | INSUFF
Lap. vs. open | RTDA (days) | 3 | MOD. | C | D | P 7.4 days earlier (CI 3.4 to 11.4) | Lap. | HIGH^*^
Lap. vs. open | RTW (days) | 3 | MOD. | C | D | I (Diff. in days, CI -13.2 to +0.34) | ? | INSUFF
Lap. vs. open | Long-term pain (% of patients) | 3 | MOD. | C | D | P OR 0.24 (CI 0.08 to 0.74) | Lap. | MOD
Lap. vs. open | Epigastric vessel injury | 2 | MOD. | I | D | I (OR 0.15 to 2.48) | ? | INSUFF^†^
Lap. vs. open | Hematoma | 1 | MOD. | U | D | I (OR 0.62 to 6.51) | ? | INSUFF^†^
Lap. vs. open | Urinary retention | 3 | MOD. | I | D | I (OR 0.27 to 1.70) | ? | INSUFF
Lap. vs. open | Wound infection | 3 | MOD. | C | D | I (OR 0.05 to 1.38) | ? | INSUFF

NA = Not applicable, OR = odds ratio, RR = relative risk, RTDA = return to activities of daily living, RTW = return to work.

Note:

For risk of bias, MOD. = Moderate.

For consistency, C = consistent, I = inconsistent, U = unknown consistency because there was only one study.

For directness, D = direct, I = indirect.

For precision, I = imprecise, P = precise.

For the column labeled “Evidence favors,” ? denotes inconclusive evidence, and EQ denotes approximate equivalence. SOE = strength of evidence.

For the column labeled SOE rating, INSUFF = insufficient,

* indicates that the SOE was upgraded due to a large magnitude of effect, and

† indicates that the SOE was downgraded due to publication bias or selective outcome reporting.

As noted in the Introduction, Kumar et al. (1999)17 suggested that Lichtenstein may be more appropriate for large recurrent hernia than small or medium-sized recurrent hernia. To address this idea, we examined the six (of eight) studies for this Key Question that used Lichtenstein as the open procedure. None of the six had enrollment criteria related to hernia size, nor baseline characteristics specifically about hernia size, nor reported data separately for hernias of different sizes. Thus, whether the Lichtenstein repair is more appropriate for large recurrent hernia is not addressed by these studies.

## Key Question 3 Do different open mesh-based repair procedures (e.g., Lichtenstein repair, mesh plug) differ in patient-oriented effectiveness outcomes and/or adverse events?

### Study Characteristics

General information about the 21 studies included for this Key Question appears in Table 35 of Appendix C. Five studies were conducted in Turkey; four in the United Kingdom; three in Sweden; two in the Netherlands; one each in Egypt, Finland, Greece, Poland, and the United States, and one was conducted both in United States and United Kingdom. Fourteen studies were single-center RCTs; two were two-center RCTs; two were three-center RCTs; one was country-wide registry study in Sweden; and the remaining two were RCTs that did not report the number of centers.

Regarding specific surgical procedures, the most commonly compared procedures were Lichtenstein versus mesh plug (seven studies), Lichtenstein versus Prolene Hernia System (PHS) (five studies), Lichtenstein versus the open peritoneal mesh (OPM) technique (three studies), mesh plug versus PHS (two studies), and Lichtenstein versus Kugel (two studies). The RCTs enrolled between 26 and 597 patients each; and the Swedish registry included 142,578 hernias repaired in that country. The dates of patient enrollment were reported by 14 of 21 studies. The average length of the enrollment period was 3.5 years (range 9 months to 14 years). Studies were typically conducted between 2000 and 2010.

Eighteen studies were conducted at university hospitals; two included some university hospitals as well as some nonuniversity hospitals; the remaining did not report the type(s) of hospitals. Funding for the study was not reported by 14 studies; government funding was reported in one study; university funding was reported in two studies; two did not report the funding source but did state they had no manufacturer ties; two reported partial manufacturer funding.

Patient enrollment criteria appear in Table 36 (hernia-related criteria), Table 37 (demographic and medical criteria), and Table 38 (other criteria) of Appendix C. Enrollment criteria varied widely among the 21 studies. The most commonly used hernia-related exclusions were recurrent hernia (13 studies), bilateral hernia (11 studies), “emergency” hernia (10 studies), femoral hernia (9 studies), and incarcerated hernia (9 studies). Others were irreducible hernia (excluded by five studies), scrotal hernia (excluded by three studies), and asymptomatic hernia (excluded by one study). One study included only bilateral hernia. Overall, the studies paint an extraordinarily diverse portrait of the types of hernias deemed relevant to the studies, even though, by virtue of inclusion, they all compared open repair of inguinal hernia to laparoscopic repair of inguinal hernia.

Regarding patient age criteria, 15 of the 21 studies (71 percent) stated that they included any adults or required age >18 years. Three (14 percent) excluded those unfit for general anesthesia or those with anesthesia risk scores of 3 or 4 or more, and three studies excluded those who had undergone a prior surgery in the lower abdomen. Five studies excluded all females, two excluded pregnant women, and two excluded those with coagulation disorders. As with the hernia-related exclusions, there was large variability in how studies selected patients for inclusion.

Treatment details appear in Table 39 of Appendix C. All reported baseline patient characteristics in the studies included for this Key Question appear in Table 40 of Appendix C.

### Risk of Bias

Our risk-of-bias assessments for the 21 studies appear in Table 41 of Appendix C. The 20 RCTs were categorized as Moderate or low risk of bias for their reported outcomes, and the one registry study that was categorized as High risk of bias.

The reasons for this latter category assignment were mentioned above in Key Question 2a (nonrandom assignment, retrospectivity, lack of concealment of allocation, outcomes assessed with knowledge of treatment, and potential selection bias). Common reasons for assigning a Moderate category to the RCTs were the same as those discussed in Key Question 2a: possible differences in prior surgical expertise, lack of concealment of allocation, and lack of outcome assessor blinding.

### Findings

All included data for this Key Question appear in Table 42 of Appendix C. To address this Key Question, multiple comparisons involving different surgical procedures were performed. Summarized below are findings for the comparisons for which two or more studies had reported data on at least one outcome of interest.

#### Lichtenstein Versus Mesh Plug (Seven Studies)

##### Hernia Recurrence

We performed a meta-analysis of three studies reporting this outcome (Figure 15), and identified a summary RR of 1.07 (95% CI, 0.33 to 3.42). The length of followup in the three studies was one year, 1.7 years, and three years. We defined the MCSD as a three-percentage-point difference between groups, to aid interpretation; we calculated the overall rate of recurrence in the Lichtenstein group, which was 1.07 percent. Multiplying a 3.42 RR with this rate yielded a corresponding rate of 3.67 percent for low-weight PP mesh group. The difference between these rates is only 2.59 percent, which is less than our predefined MCSD of three percentage points. This suggests approximate equivalence in recurrence rates.

Figure 15 Key Question 3: Lichtenstein versus mesh plug, meta-analysis of recurrence

(I^2^=0%, tau=0)

The figure shows the results of a meta-analysis comparing Lichtenstein and mesh plug on the outcome Recurrence in the context of painful hernia in adults. Points to the left of the midline favor Lichtenstein, whereas points to the right of the midline favor mesh plug. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

##### Length of Hospital Stay

None of the studies of this comparison reported this outcome.

##### Return to Daily Activities

Two studies reported this outcome, and were included in a meta-analysis of number of days before returning to normal daily activities (Figure 16). The meta-analysis was inconclusive (summary difference in means: -4.38 days; 95% CI, -13.17 to 4.41).

Figure 16 Key Question 3: Lichtenstein versus mesh plug, meta-analysis of return to activities of daily living

(I^2^=74%, tau=31.3)

The figure shows the results of a meta-analysis comparing Lichtenstein and mesh plug on the outcome Return to Activities of Daily Living in the context of painful hernia in adults. Points to the left of the midline favor Lichtenstein, whereas points to the right of the midline favor mesh plug. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

##### Return to Work

Two studies reported return-to-work data, and were combined in a meta-analysis. The meta-analysis (Figure 17) indicated shorter time to return to work after Lichtenstein repair (summary difference in means: -4.0; 95% CI, -6.97 to -1.02). This is larger than what we defined as the MCSD for this outcome (1 day).

Figure 17 Key Question 3: Lichtenstein versus mesh plug, meta-analysis of return to work

(I^2^=0%, tau=0)

The figure shows the results of a meta-analysis comparing Lichtenstein and mesh plug on the outcome Return to Work in the context of painful hernia in adults. Points to the left of the midline favor Lichtenstein, whereas points to the right of the midline favor mesh plug. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

##### Short-Term Pain

Four studies reporting short-term pain on VAS (<1 month after surgery) were included in a meta-analysis (Figure 18). The meta-analysis was inconclusive (summary difference in means: -1.48; 95% CI, -3.36 to 0.39 points on a 0–10 scale).

Figure 18 Key Question 3: Lichtenstein versus mesh plug, meta-analysis of short-term pain

(I^2^=97%, tau=3.5)

The figure shows the results of a meta-analysis comparing Lichtenstein and mesh plug on the outcome Short-Term Pain in the context of painful hernia in adults. Points to the left of the midline favor Lichtenstein, whereas points to the right of the midline favor mesh plug. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

##### Intermediate-Term Pain

None of the studies of this comparison reported this outcome.

##### Adverse Events

We conducted meta-analyses of four types of adverse events (seroma reported by three studies, hematoma reported by five studies, wound infection reported by five studies, and urinary retention reported by two studies) (Figure 19, Figure 20, Figure 21, and Figure 22, respectively). A clear direction of effect was found for one event: seroma (lower rates with Lichtenstein repair, OR=0.39; 95% CI, 0.16 to 0.94). For the other three events, the evidence was inconclusive.

Figure 19 Key Question 3: Lichtenstein versus mesh plug, meta-analysis of seroma

(I^2^=0%, tau=0)

The figure shows the results of a meta-analysis comparing Lichtenstein and mesh plug on the outcome Seroma in the context of painful hernia in adults. Points to the left of the midline favor Lichtenstein, whereas points to the right of the midline favor mesh plug. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

Figure 20 Key Question 3: Lichtenstein versus mesh plug, meta-analysis of hematoma

(I^2^=14%, tau=0.06)

The figure shows the results of a meta-analysis comparing Lichtenstein and mesh plug on the outcome Hematoma in the context of painful hernia in adults. Points to the left of the midline favor Lichtenstein, whereas points to the right of the midline favor mesh plug. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

Figure 21 Key Question 3: Lichtenstein versus mesh plug, meta-analysis of infection

(I^2^=0%, tau=0)

The figure shows the results of a meta-analysis comparing Lichtenstein and mesh plug on the outcome Infection in the context of painful hernia in adults. Points to the left of the midline favor Lichtenstein, whereas points to the right of the midline favor mesh plug. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

Figure 22 Key Question 3: Lichtenstein versus mesh plug, meta-analysis of urinary retention

(I^2^=35%, tau=0.72)

The figure shows the results of a meta-analysis comparing Lichtenstein and mesh plug on the outcome Urinary Retention in the context of painful hernia in adults. Points to the left of the midline favor Lichtenstein, whereas points to the right of the midline favor mesh plug. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

#### Lichtenstein Versus Prolene Hernia System (Five Studies)

##### Hernia Recurrence

We performed a meta-analysis of four studies reporting this outcome (Figure 23), and found a summary RR=2.53; 95% CI, 0.56 to 11.45). We had defined the MCSD as a three-percentage-point difference between groups, to aid interpretation; we calculated the overall rate of recurrence in the Lichtenstein repair groups, which was 1.3 percent. Applying an RR of 2.53 to this rate yields a Lichtenstein recurrence rate of 3.3; applying it to the lower bound of RR 0.56 yields a lower percentage of 0.7 percent; applying it to the upper bound of RR=11.45 yields an upper bound of 14.9 percent. Thus the difference in percentages could be as high as 14.2 percent (14.9 percent to 0.7 percent), which is higher than our MCSD of three percentage points. Thus, the evidence is too imprecise to permit a conclusion.

Figure 23 Key Question 3: Lichtenstein versus Prolene Hernia System, meta-analysis of recurrence

(I^2^=0%, tau=0)

The figure shows the results of a meta-analysis comparing Lichtenstein and Prolene Hernia System on the outcome Recurrence in the context of painful hernia in adults. Points to the left of the midline favor Lichtenstein, whereas points to the right of the midline favor Prolene Hernia System. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

##### Length of Hospital Stay

One study found equivalence for this outcome (difference in means -0.03 days; 95% CI, -0.29 to 0.23).

##### Return to Daily Activities

None of the studies of this comparison reported this outcome.

##### Return to Work

Two studies reported RTW data, and were combined in a meta-analysis (Figure 24). The meta-analysis was inconclusive (summary difference in means -4.57 days; 95% CI, -15.74 to 6.6).

Figure 24 Key Question 3: Lichtenstein versus Prolene Hernia System, meta-analysis of return to work

(I^2^=0%, tau=0)

The figure shows the results of a meta-analysis comparing Lichtenstein and Prolene Hernia System on the outcome Return to Work in the context of painful hernia in adults. Points to the left of the midline favor Lichtenstein, whereas points to the right of the midline favor Prolene Hernia System. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

##### Short-Term Pain

Two studies reporting short-term pain using VAS (≤1 month after surgery) were included in a meta-analysis (Figure 25). We found equivalence comparing Lichtenstein to PHS (summary difference in means: -0.03; 95% CI, -0.37 to 0.31, points on a 0–10 scale).

Figure 25 Key Question 3: Lichtenstein versus Prolene Hernia System, meta-analysis of short-term pain

(I^2^=0%, tau=0)

The figure shows the results of a meta-analysis comparing Lichtenstein and Prolene Hernia System on the outcome Short-Term Pain in the context of painful hernia in adults. Points to the left of the midline favor Lichtenstein, whereas points to the right of the midline favor Prolene Hernia System. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

##### Intermediate-Term Pain

Two studies reporting short-term pain using VAS (>1 month but ≤6 months after surgery) were included in a meta-analysis (Figure 26). The meta-analysis was inconclusive (summary difference in means: -1.03; 95% CI, -2.4 to 0.33, points on a 0–10 scale).

Figure 26 Key Question 3: Lichtenstein versus Prolene Hernia System, meta-analysis of intermediate-term pain

(I^2^=0%, tau=0)

The figure shows the results of a meta-analysis comparing Lichtenstein and Prolene Hernia System on the outcome Intermediate-Term Pain in the context of painful hernia in adults. Points to the left of the midline favor Lichtenstein, whereas points to the right of the midline favor Prolene Hernia System. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

##### Adverse Events

We conducted meta-analyses of two types of adverse events (hematoma reported by two studies and wound infection reported by three studies) (Figure 27 and Figure 28, respectively). The evidence was inconclusive for both events.

Figure 27 Key Question 3: Lichtenstein versus Prolene Hernia System, meta-analysis of hematoma

(I^2^=0%, tau=0)

The figure shows the results of a meta-analysis comparing Lichtenstein and Prolene Hernia System on the outcome Hematoma in the context of painful hernia in adults. Points to the left of the midline favor Lichtenstein, whereas points to the right of the midline favor Prolene Hernia System. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

Figure 28 Key Question 3: Lichtenstein versus Prolene Hernia System, meta-analysis of infection

(I^2^=3%, tau=0.02)

The figure shows the results of a meta-analysis comparing Lichtenstein and Prolene Hernia System on the outcome Infection in the context of painful hernia in adults. Points to the left of the midline favor Lichtenstein, whereas points to the right of the midline favor Prolene Hernia System. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

#### Lichtenstein Versus Open Preperitoneal Mesh (Three Studies)

##### Hernia Recurrence

None of the studies of this comparison reported this outcome.

##### Length of Hospital Stay

One study reported an outcome in this category, and the evidence was inconclusive (difference in means -0.4; 95% CI, -1.03 to 0.23).

##### Return to Daily Activities

One study reported an outcome in RTDA, and the evidence was inconclusive (difference in means -0.16; 95% CI, -1.87 to 1.55).

##### Return to Work

One study reported an outcome in RTW, and the evidence was inconclusive (difference in means -0.88; 95% CI, -2.66 to 0.9).

##### Short-Term Pain

One study reporting short-term pain using VAS (≤1 month after surgery) was evaluated and found equivalence comparing Lichtenstein to OPM (difference in means -0.27; 95% CI, -1.35 to 0.81, points on a 0–10 scale).

##### Intermediate-Term Pain

None of the studies of this comparison reported this outcome.

##### Adverse Events

One study reported hematoma (no events in the Lichtenstein vs. one event in the OPM group) and another reported wound infection (one event the Lichtenstein vs. one event in the OPM group). The evidence was inconclusive for both events.

#### Mesh Plug Versus Prolene Hernia System (Two Studies)

##### Hernia Recurrence

One study reported recurrence (one recurrence in mesh plug vs. none in the PHS group), and the evidence was inconclusive.

##### Length of Hospital Stay

None of the studies of this comparison reported this outcome.

##### Return to Daily Activities

None of the studies of this comparison reported this outcome.

##### Return to Work

None of the studies of this comparison reported this outcome.

##### Short-Term Pain

Two studies reporting short-term pain using VAS (≤1 month after surgery) were evaluated using meta-analysis (Figure 29) and found equivalence comparing mesh plug to PHS (difference in means -0.07; 95% CI, -0.41 to 0.27, points on a 0–10 scale).

Figure 29 Key Question 3: Mesh plug versus Prolene Hernia System, meta-analysis of short-term pain

(I^2^=0%, tau=0)

The figure shows the results of a meta-analysis comparing Mesh plug and Prolene Hernia System on the outcome Short-Term Pain in the context of painful hernia in adults. Points to the left of the midline favor Mesh plug, whereas points to the right of the midline favor Prolene Hernia System. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

##### Intermediate-Term Pain

None of the studies of this comparison reported this outcome.

##### Adverse Events

One study reported hematoma and wound infection. The evidence was inconclusive for both events.

#### Lichtenstein Versus Kugel (Two Studies)

##### Hernia Recurrence

One study reported data on recurrence (one recurrence in Lichtenstein group vs. none in the Kugel group), and the evidence was inconclusive.

##### Length of Hospital Stay

None of the studies of this comparison reported this outcome.

##### Return to Daily Activities

None of the studies of this comparison reported this outcome.

##### Return to Work

None of the studies of this comparison reported this outcome.

##### Short-Term Pain

One study reporting short-term pain using VAS (≤1 month after surgery) was evaluated and found equivalence comparing Lichtenstein to Kugel (difference in means: -0.3; 95% CI, -0.91 to 0.31, points on a 0–10 scale).

##### Intermediate-Term Pain

One study reporting intermediate-term pain using VAS (>1 month but ≤6 months after surgery) was evaluated and found equivalence comparing Lichtenstein to Kugel (difference in means: -0.6; 95% CI, -1.21 to 0.01, points on a 0–10 scale).

##### Adverse Events

One study reported hematoma, seroma, and wound infection. The evidence was inconclusive for all three events.

### Applicability

Twenty-one studies are included for review for Key Question 3. We evaluated these studies to identify factors that might affect the applicability of the evidence. As described in the Methods section, the goal of the evaluation is to raise stakeholders' attention to potential applicability issues embedded in the evidence rather than generating a rating or score for the applicability.

The studies reviewed for Key Question 3 compared various open mesh-based procedures for hernia repair, including Lichtenstein, mesh plug (using the Perfix or Proloop device), Trabucco (using the Hertra device), “preperitoneal mesh,” “plug,” PHS, Kugel, Nyhus, “open properitoneal mesh,” Stoppa, and Read-Rives methods. Lichtenstein and mesh plug are the most commonly compared procedures in these studies. Table 39 in Appendix C provides a detailed description of the procedures being compared in the studies. For Key Question 3, we summarized the findings separately by each comparison of surgical procedures, because the evidence for one set of comparisons does not apply to a different set of comparisons.

Fourteen of the 21 studies reviewed for Key Question 3 reported the date range of the surgeries being performed. In these studies, the majority of the surgeries were performed in 1990s and early 2000s. The other seven studies reviewed for Key Question 3 did not report a date range for surgeries. This body of evidence for Key Question 3 may not necessarily reflect the comparative performance of the procedures that are performed currently.

Most of the studies included for review for Key Question 3 did not report the surgeons' prior experience for the procedures being compared. Only two studies reported these data. One study primarily depended on “surgeons in training,” and the other one used “highly experienced” surgeons.56,67 No study reported the number of prior cases or years of practice of the surgeons. Given the limitation in the data reported, we were unable to judge what implication surgeons' experience may have in the applicability of the evidence. Table 39 in Appendix C provides additional detail on the surgical procedures compared in the studies, including data on surgeons' experiences.

Patient enrollment criteria and reported baseline characteristics varied significantly across the 21 studies. While most studies included all adult patients, several studies only included patients older than 30 or 40 years of age.19,56,114 Many studies excluded patients with recurrent, bilateral, incarcerated, strangulated, or femoral hernias. Five studies excluded all female patients.19,20,56,115,116 Based on the data reported, we did not identify any clear patterns in the patient characteristics of the studies that indicate significant impact on the applicability of the evidence. Detailed patient enrollment criteria and baseline characteristics of these studies are provided in Appendix C in Table 36 and Table 40.

Except for two studies,18,116 all other studies were performed outside of the United States—13 studies from European countries, 5 from Turkey, and 1 from Egypt. The differences in health care systems and practice patterns between the United States and other regions might affect applicability of the evidence from the perspectives of U.S. stakeholders. Except for three studies56,117-125 all other 18 studies were performed in university hospitals. The evidence for Key Question 3 is potentially more applicable to academic clinical settings. Detailed information on geographic and clinical settings of the 21 studies is provided in Table 35 in Appendix C.

### Summary of Key Question 3

A summary of the comparisons and outcomes we examined in this Key Question is provided in Table 7 below. Of the 31 outcomes, the evidence was sufficient to permit a conclusion for eight outcomes:

- Two outcomes favored Lichtenstein compared with mesh plug (RTW and seroma)
- One outcome indicated approximate equivalence of the Lichtenstein procedure to mesh plug (RC)
- One outcome indicated approximate equivalence of Lichtenstein to PHS (short-term pain)
- One outcome indicated approximate equivalence of Lichtenstein to OPM (short-term pain)
- One outcome indicated approximate equivalence of mesh plug to PHS (short-term pain)
- Two outcomes indicated approximate equivalence comparing Lichtenstein to Kugel (short-term pain, intermediate-term pain).

Table 7 Key Question 3: Strength of evidence ratings

Comparison | Outcome | # Studies | Overall Risk of Bias | Consistency | Directness | Precision | Evidence Favors | SOE Rating
Lichtenstein vs. mesh plug | Recurrence | 3 | MOD | C | D | P RR 1.07 (CI 0.33 to 3.42) | EQ | MOD
Lichtenstein vs. mesh plug | Return to daily activities (days) | 2 | MOD | I | D | I Diff in means -4.38 (CI -13.17 to 4.41) | ? | INSUFF^*^
Lichtenstein vs. mesh plug | Return to work (days) | 2 | MOD | C | D | P Diff in means -4 (CI -6.97 to -1.02) | Lichtenstein | MOD^*,†^
Lichtenstein vs. mesh plug | Short-term pain (measured in VAS) | 4 | MOD | I | D | I Diff in means -1.48 (CI -3.36 to 0.39) | ? | INSUFF
Lichtenstein vs. mesh plug | Seroma | 3 | MOD | C | D | P OR 0.39 (CI 0.16 to 0.94) | Lichtenstein | MOD
Lichtenstein vs. mesh plug | Hematoma | 5 | MOD | C | D | I OR 0.8 (CI 0.47 to 1.37) | ? | INSUFF
Lichtenstein vs. mesh plug | Wound infection | 5 | MOD | C | D | I OR 1.55 (CI 0.79 to 3.05) | ? | INSUFF
Lichtenstein vs. mesh plug | Urinary retention | 2 | MOD | C | D | I OR 2.17 (CI 0.36 to 13.1) | ? | INSUFF
Lichtenstein vs. PHS | Recurrence | 4 | MOD | C | D | I RR 2.53 (CI 0.56 to 11.45) | ? | INSUFF
Lichtenstein vs. PHS | Length of stay (days) | 1 | MOD | U | D | P Diff in means -0.03 (CI -0.29 to 0.23) | ? | INSUFF^†^
Lichtenstein vs. PHS | Return to work (days) | 2 | MOD | I | D | I Diff in means-4.57 (CI -15.74 to 6.6) | ? | INSUFF
Lichtenstein vs. PHS | Short-term pain (measured in VAS) | 2 | MOD | C | D | P Diff in means -0.03 (CI -0.37 to 0.31) | EQ | MOD
Lichtenstein vs. PHS | Intermediate-term pain (measured in VAS) | 2 | MOD | I | D | I Diff means -1.03 (CI -2.4 to 0.33) | ? | INSUFF
Lichtenstein vs. PHS | Hematoma | 2 | MOD | C | D | I OR 0.49 (CI 0.21 to 1.14) | ? | INSUFF
Lichtenstein vs. PHS | Wound infection | 3 | MOD | C | D | I OR 0.99 (CI 0.48 to 2.06) | ? | INSUFF
Lichtenstein vs. OPM | Length of stay (days) | 1 | MOD | U | D | I Diff in means -0.4 (CI -1.03 to 0.23) | ? | INSUFF
Lichtenstein vs. OPM | Return to daily activities (days) | 1 | MOD | U | D | I Diff in means -0.16 (CI -1.87 to 1.55) | ? | INSUFF
Lichtenstein vs. OPM | Return to work (days) | 1 | MOD | U | D | I Diff in means -0.88 (CI -2.66 to 0.9) | ? | INSUFF
Lichtenstein vs. OPM | Short-term pain (measured in VAS) | 1 | MOD | U | D | P Diff in means -0.27 (CI -1.35 to 0.81) | EQ | LOW
Lichtenstein vs. OPM | Hematoma | 1 | MOD | U | D | I OR 0.32 (CI 0.01 to 8.23) | ? | INSUFF
Lichtenstein vs. OPM | Wound infection | 1 | MOD | U | D | I OR 1 (CI 0.06 to 16.93) | ? | INSUFF
Mesh plug vs. PHS | Recurrence | 1 | MOD | U | D | I RR 2.87 (CI 0.12 to 69.76) | ? | INSUFF
Mesh plug vs. PHS | Short-term pain (measured in VAS) | 2 | MOD | C | D | P Diff in means -0.07 (CI -0.41 to 0.27) | EQ | MOD
Mesh plug vs. PHS | Hematoma | 1 | MOD | U | D | I OR 0.83 (CI 0.39 to 1.75) | ? | INSUFF
Mesh plug vs. PHS | Wound infection | 1 | MOD | U | D | I OR 6.36 (CI 0.76 to 53.48) | ? | INSUFF
Lichtenstein vs. Kugel | Recurrence | 1 | MOD | U | D | I RR 3 (CI 0.12 to 72.41) | ? | INSUFF
Lichtenstein vs. Kugel | Short-term pain (measured in VAS) | 1 | MOD | U | D | P Diff in means -0.3 (CI -0.91 to 0.31) | EQ | LOW
Lichtenstein vs. Kugel | Intermediate-term pain (measured in VAS) | 1 | MOD | U | D | P Diff in means -0.6 (CI -1.21 to 0.01) | EQ | LOW
Lichtenstein vs. Kugel | Hematoma | 1 | MOD | U | D | I OR 0.33 (CI 0.01 to 8.21) | ? | INSUFF
Lichtenstein vs. Kugel | Seroma | 1 | MOD | U | D | I OR 0.33 (CI 0.01 to 8.21) | ? | INSUFF
Lichtenstein vs. Kugel | Wound infection | 1 | MOD | U | D | I OR 0.33 (CI 0.01 to 8.21) | ? | INSUFF

Diff = difference, OR = odds ratio, RR = relative risk, VAS = visual analog scale.

Note:

For consistency, C = consistent, I = inconsistent, U = unknown consistency because there was only one study.

For directness, D = direct, I = indirect.

For precision, I = imprecise, P = precise.

For the column labeled “Evidence favors,” ? denotes inconclusive evidence, and EQ denotes approximate equivalence.

For the column labeled SOE rating, SOE = strength of evidence, INSUFF = insufficient,

* indicates that the SOE was upgraded due to a large magnitude of effect. and

† indicates that the SOE was downgraded due to publication bias or selective outcome reporting.

Our ratings of the SOE for these outcomes also appear in Table 7. Most studies were at moderate risk of bias (see the pertinent section above); some inconsistencies were found for some outcomes based on effect sizes on opposite sides of a null effect; all of these outcomes are directly important to clinicians and patients; some imprecision was found for some outcomes that precluded conclusions. Four outcomes (return to daily activity, return to work, urinary retention, hematoma) for the Lichtenstein versus mesh plug comparison were judged to potentially be associated with publication bias, specifically in the form of selective outcome reporting (for example, only two of seven studies reported these outcomes, and the authors' choice to report that data may have been influenced by the nature of the findings). Likewise, length of stay for the Lichtenstein versus PHS comparison was judged to potentially be associated with publication bias, also in the form of selective outcome reporting (only one of five studies reported this outcome).

Six non-English studies might have met the inclusion criteria for this Key Question if we had not required that studies be published in English.126-131 Four of these were clearly RCTs, one non-RCT, and one may have been randomized (the abstract was unclear on this point).We summarize the results as follows:

- One study126 (possibly randomized, comparing Lichtenstein with PHS) stated that authors assessed length of stay, RTDA, and pain. However, the findings were not reported in the abstract.
- One non-RCT127 (comparing PHS with Lichtenstein) found no complications and reported patient SFN after Lichtenstein and PHS.
- One RCT128 (comparing Trabucco vs. plug-and-patch vs. Lichtenstein) reported a higher incidence of postoperative hematoma in the Lichtenstein group. None of our included studies directly compared any of these procedures with each other.
- One RCT129 (comparing PHS with mesh plug) reported that more patients in the mesh plug group complained of numbness than those in the PHS group. However, numbness was not reported by the two included studies in our review that compared PHS to mesh plug.
- One RCT132 (comparing peritoneal mesh graft with Lichtenstein in patients with recurrent hernia) found one re-recurrence in the mesh group and three re-recurrences in the Lichtenstein group at long-term followup (1–4 years).
- One RCT131 (comparing Lichtenstein with mesh plug) reported there were no recurrences in both groups.

## Key Question 4 Do different laparoscopic mesh-based repair procedures (e.g., transabdominal preperitoneal repair, totally extraperitoneal repair) differ in patient-oriented effectiveness outcomes and/or adverse events?

### Study Characteristics

General information about the 11 studies included for this Key Question appears in Table 43 of Appendix C. Two studies each were conducted in Austria, China, and Turkey; and the rest were each conducted in Egypt, Greece, India, Italy, and the United States. Eight studies were single-center RCTs; one was multicenter RCT; and the remaining two were RCTs that did not report number of centers.

Regarding specific surgical procedures, the most commonly compared procedures were TAPP versus TEP (nine studies). The other two studies compared different variants types of surgical approaches for TEP or TEP versus IPOM. The RCTs enrolled between 44 and 144 patients each. The dates of patient enrollment were reported by five of the eight studies. The average length of the enrollment period was 3.9 years (range 1.5–5.8 years).

Six studies were conducted at university hospitals; one at a surgical laparoscopic institute; one at a nonuniversity hospital; one at a surgery clinic; and the remaining two did not report the type(s) of hospitals. Funding for the study was not reported by eight studies; government funding was reported in one study; university funding was reported in one study; and one did not report the funding source but did state that it had no manufacturer ties.

Patient enrollment criteria appear in Table 44 (hernia-related criteria), Table 45 (demographic and medical criteria), and Table 46 (other criteria) of Appendix C. Enrollment criteria varied widely among the 11 studies. The most commonly used hernia-related exclusions were recurrent hernia (eight studies), bilateral hernia (8 studies), and incarcerated hernia (six studies). Others were femoral hernia (excluded by one study) and giant hernia (one study). Overall, the studies paint an extraordinarily diverse portrait of the types of hernias deemed relevant to the studies, even though, by virtue of inclusion, they all compared TAPP repair of inguinal hernia to either TEP or IPOM repair of inguinal hernia.

Regarding patient age criteria, 8 of the 11 studies stated that they included any adults or required patients aged older than 18 years. Six excluded patients that were unfit for general anesthesia or those with anesthesia risk scores of 3 or 4 or more, and two studies excluded those who had undergone a prior surgery in the lower abdomen. Two studies excluded all females, one excluded patients with ascites, and two excluded those with coagulation disorders. As with the hernia-related exclusions, there was large variability in how studies selected patients for inclusion.

Treatment details appear in Table 47 of Appendix C. None of the studies reported the actual number of prior hernia repairs the surgeons had performed. Instead, all 11 studies simply said surgeon had general skills that were not specific to hernia repair. Two of the 11 studies stated that all operations were performed by one consultant surgeon.

All reported baseline patient characteristics in the studies included for this Key Question appear in Table 48 of Appendix C.

### Risk of Bias

Our risk-of-bias assessments for the 11 studies appear in Table 49 of Appendix C. Eight RCTs were categorized as Moderate risk of bias for all of their reported outcomes. Three RCTs were categorized as Low risk of bias for all of their reported outcomes. Common reasons for assigning a Moderate category to the studies were the same as those discussed in Key Question 2a: possible differences in prior surgical expertise, lack of concealment of allocation, and lack of outcome assessor blinding.

### Findings

All extracted data for this Key Question appear in Table 50 of Appendix C. Described below are studies that compared TAPP with TEP.

#### Transabdominal Preperitoneal Repair Versus Totally Extraperitoneal Repair (Nine Studies)

##### Hernia Recurrence

We performed a meta-analysis of five studies reporting this outcome and found that the evidence was inconclusive (summary RR 0.86; 95% CI, 0.30 to 2.50) (Figure 30).

Figure 30 Key Question 4: Transabdominal preperitoneal repair versus totally extraperitoneal repair, meta-analysis of recurrence

(I^2^=0%, tau=0)

The figure shows the results of a meta-analysis comparing TAPP and TEPP on the outcome Recurrence in the context of painful hernia in adults. Points to the left of the midline favor TAPP, whereas points to the right of the midline favor TEPP. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

##### Length of Hospital Stay

Five studies reported this outcome and were included in a meta-analysis (Figure 31). The meta-analysis was inconclusive (summary difference in means -0.04 days; 95% CI, -0.12 to 0.04).

Figure 31 Key Question 4: Transabdominal preperitoneal repair versus totally extraperitoneal repair, meta-analysis of length of stay

(I^2^=8.76%, tau=0.03)

The figure shows the results of a meta-analysis comparing TAPP and TEPP on the outcome Length of Stay in the context of painful hernia in adults. Points to the left of the midline favor TAPP, whereas points to the right of the midline favor TEPP. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

##### Return to Daily Activities

Two studies reported RTDA and were included in a meta-analysis (Figure 32). This meta-analysis of number of days before returning to normal daily activities was inconclusive (summary difference in means -5.88 days; 95% CI, -17.84 to 6.09).

Figure 32 Key Question 4: TAPP versus TEPP, meta-analysis of return to activities of daily living

(I^2^=93%, tau=0.98)

The figure shows the results of a meta-analysis comparing TAPP and TEPP on the outcome Return to Activities of Daily Living in the context of painful hernia in adults. Points to the left of the midline favor TAPP, whereas points to the right of the midline favor TEPP. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

##### Return to Work

Four studies reported return-to-work data and three were combined in a meta-analysis (Figure 33). A fourth study that reported outcome data as return to “unrestricted” work was not included in the meta-analysis. The meta-analysis indicated shorter time-to-return-to-work after TAPP repair (summary difference in means -1.44 days; 95% CI, -2.65 to -0.23). The 95% confidence of interval spans the value that we defined as the MCSD for the outcome (one day). Therefore, it is unclear whether the difference found is clinically significant.

Figure 33 Key Question 4: Transabdominal preperitoneal repair versus totally extraperitoneal repair, meta-analysis of return to work

(I^2^=0%, tau=0)

The figure shows the results of a meta-analysis comparing TAPP and TEPP on the outcome Return to Work in the context of painful hernia in adults. Points to the left of the midline favor TAPP, whereas points to the right of the midline favor TEPP. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

##### Short-Term Pain (Measured in Visual Analog Scale)

Five studies reporting short-term pain (1 month or less after surgery) on the pain (measured in VAS) scale were included in a meta-analysis (Figure 34). This analysis found approximately equivalent rates of short-term pain (summary difference in means: -0.11; 95% CI, -0.25 to 0.03 points on a 0–10 scale).

Figure 34 Key Question 4: Transabdominal preperitoneal repair versus totally extraperitoneal repair, meta-analysis of short-term pain

(I^2^=6.87%, tau=0.05)

The figure shows the results of a meta-analysis comparing TAPP and TEPP on the outcome Short-Term Pain in the context of painful hernia in adults. Points to the left of the midline favor TAPP, whereas points to the right of the midline favor TEPP. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

##### Intermediate-Term Pain (Measured in Visual Analog Scale)

Only one study reported data on this outcome at 3 months, and the results suggested equivalence on the 0–10 VAS scale (1.28 ± 0.45 in the TAPP group vs. 1.09 ± 0.45 in the TEP).

##### Long-Term Pain (Measured in Visual Analog Scale)

Only one study reported data on this outcome at 38 months, and the results suggested equivalence on the 0–10 VAS scale (none in the TAPP group vs. none in the TEP group).

##### Adverse Events

We conducted meta-analyses of three types of events (hematoma [four studies], urinary retention [five studies], and wound infection [six studies]) (Figure 35, Figure 36, and Figure 37, respectively). The evidence was inconclusive for hematoma (OR=1.15; 95% CI, 0.33 to 4.00), urinary retention (OR=0.80; 95% CI, 0.31 to 2.03), and wound infection (OR=1.47; 95% CI, 0.33 to 6.55).

Figure 35 Key Question 4: Transabdominal preperitoneal repair versus totally extraperitoneal repair, meta-analysis of hematoma

(I^2^=0%, tau=0)

The figure shows the results of a meta-analysis comparing TAPP and TEPP on the outcome Hematoma in the context of painful hernia in adults. Points to the left of the midline favor TAPP, whereas points to the right of the midline favor TEPP. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

Figure 36 Key Question 4: Transabdominal preperitoneal repair versus totally extraperitoneal repair, meta-analysis of urinary retention

(I^2^=0%, tau=0)

The figure shows the results of a meta-analysis comparing TAPP and TEPP on the outcome Urinary Retention in the context of painful hernia in adults. Points to the left of the midline favor TAPP, whereas points to the right of the midline favor TEPP. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

Figure 37 Key Question 4: Transabdominal preperitoneal repair versus totally extraperitoneal repair, meta-analysis of infection

(I^2^=0%, tau=0)

The figure shows the results of a meta-analysis comparing TAPP and TEPP on the outcome Infection in the context of painful hernia in adults. Points to the left of the midline favor TAPP, whereas points to the right of the midline favor TEPP. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

### Applicability

Eleven studies are included for review for Key Question 4. We evaluated these studies to identify factors that could potentially affect the applicability of the evidence. As described in the Methods section, the goal of the evaluation is to raise stakeholders' awareness of potential applicability issues embedded in the evidence rather than generating a rating or score for the applicability.

Nine of the 11 studies compared two laparoscopic procedures for hernia repair—TAPP and TEP. One study compared TEP and IPOM,133 while another study compare four different types of TEP.134 Table 47 of Appendix C provides a detailed description of the procedures being compared in the studies. For Key Question 4, we summarized the evidence by different comparison of surgical procedures, because the evidence for one set of comparisons does not apply to a different set of comparisons.

Seven of the 11 studies included for review reported the date range of the surgeries performed.67,92,93,133-137 In four of the seven studies, the surgeries were performed in 1990s to early 2000s.67,92,93,133,135 In the other three studies, the surgeries were performed from 2004 to 2009.^134,136,137^ The other four studies reviewed for Key Question 4 did not report a date range of surgeries being performed. The body of evidence for Key Question 4 may not necessarily reflect the comparative performance of the procedures that are performed at the current time.

Surgeons' prior experience with the procedures being compared varied across the studies (not all studies reported this data). Some studies reported that more senior surgeons had been used, while other studies reported using surgeons who might have needed supervision. No study reported the number of prior cases or years of practice of the surgeons. Given the data reported, we were unable to judge what implication surgeons' experience may have for the applicability of the evidence. Table 47 of Appendix C provides additional detail on the surgical procedures compared in the studies, including data on surgeons' prior experience with the procedures.

Most of the studies reviewed for Key Question 4 excluded patients with recurrent, bilateral, or incarcerated hernias. Most studies also excluded patients unfit for general anesthesia. The evidence might be less applicable to these patient populations being excluded from the studies. Other patient enrollment criteria used varied significantly across the studies. For example, some studies excluded patients with giant or strangulated hernia, while other studies excluded female patients or patients with an ASA score >3. Detailed patient enrollment criteria and baseline characteristics of these studies are provided in Table 44 and Table 48 of Appendix C.

Except for a smaller study (with 66 patients),57 all other studies were performed outside of the United States—two each from Austria, China, and Turkey, and one study each from Egypt, Greece, India, and Italy. The differences in health care systems and practice patterns between the United States and other regions might have an impact on the applicability of the evidence from the perspectives of U.S. stakeholders. The clinical settings in these studies range from general surgical clinics, to specialized surgical institute, to academic medical centers. Based on the data reported, it is unclear how the clinical settings of the studies might have affected the applicability of the evidence. Detailed information on geographic and clinical settings of the six studies is provided in Table 43 of Appendix C.

### Summary of Key Question 4

A summary of the comparisons and outcomes we examined for Key Question 4 is in Table 8 below. Of the 10 outcomes, the evidence was sufficient to permit a conclusion for four outcomes:

- One outcome favored TAPP compared with TEP (RTW)
- One outcome indicated equivalence for TAPP versus TEP (short-term pain)
- One outcome indicated equivalence for TAPP versus TEP (intermediate-term pain)
- One outcome indicated equivalence for TAPP versus TEP (long-term pain)

Table 8 Key Question 4: Strength of evidence ratings

Comparison | Outcome | # Studies | Overall Risk of Bias | Consistency | Directness | Precision | Evidence Favors | SOE Rating
TAPP vs. TEP | Recurrence | 5 | MOD | C | D | I RR 0.86 (CI 0.30 to 2.50) | ? | INSUFF
TAPP vs. TEP | Length of stay (days) | 5 | MOD | I | D | I Diff in means -0.04 (CI -0.12 to 0.04) | ? | INSUFF
TAPP vs. TEP | Return to daily activities (days) | 2 | MOD | I | D | I Diff in means -5.88 (CI -17.84 to 6.09) | ? | INSUFF^*^
TAPP vs. TEP | Return to work (days) | 3 | MOD | C | D | P Diff in means -1.44 (CI -2.65 to -0.23) | TAPP | MOD
TAPP vs. TEP | Short-term pain (measured in VAS) | 5 | MOD | C | D | P Diff in means -0.11 (CI -0.25 to 0.03) | EQ | MOD
TAPP vs. TEP | Intermediate-term pain (measured in VAS | 1 | MOD | U | D | P (CI CI not reported, but p=0.001) | EQ | LOW
TAPP vs. TEP | Long-term pain (measured in VAS | 1 | MOD | U | D | P (CI CI and p not reported) | EQ | LOW
TAPP vs. TEP | Hematoma | 4 | MOD | C | D | I OR 1.15 (CI 0.33 to 4.00) | ? | INSUFF
TAPP vs. TEP | Urinary retention | 5 | MOD | C | D | I OR 0.80 (CI 0.31 to 2.03) | ? | INSUFF
TAPP vs. TEP | Wound infection | 6 | MOD | C | D | I OR 1.47 (CI 0.33 to 6.55) | ? | INSUFF

Diff = difference, OR = odds ratio, RR = relative risk, VAS = visual analog scale

For consistency, C = consistent, I = inconsistent, U = unknown consistency because there was only one study.

For directness, D = direct, I = indirect.

For precision, I = imprecise, P = precise.

For the column labeled “Evidence favors,” ? denotes inconclusive evidence, and EQ denotes approximate equivalence.

For the column labeled SOE rating, SOE = strength of evidence, INSUFF = insufficient,

* indicates that the SOE was upgraded due to a large magnitude of effect. and

† indicates that the SOE was downgraded due to publication bias or selective outcome reporting.

Our ratings of the SOE for these outcomes also appear in Table 8. The majority of the studies were at Moderate risk of bias (see the pertinent section above); we found some inconsistencies for some outcomes based on effect sizes on opposite sides of a null effect; all of these outcomes are directly important to clinicians and patients; imprecision was found for some outcomes that precluded conclusions. One of the outcomes for the TAPP versus TEP comparison (RTDA) was judged to potentially be associated with publication bias, specifically in the form of selective outcome reporting. Only two of the nine studies reported RTDA, and the authors' choice to report that data may have been influenced by the nature of the findings.

One non-English study might have met the inclusion criteria for this Key Question if we had not required that studies be published in English.138 The study may have been randomized (the abstract was unclear on this point).The study compared TAPP versus TEP and found reduced length of stay after TEP.

## Key Question 5 Do different mesh products differ in patient-oriented effectiveness outcomes and/or adverse events?

Surgical mesh products for hernia repair are typically made from PP or polyester. However, other materials such as polytetrafluoroethylene (PTFE), polyglactin, polyglycolic acid, and polyamide are also used.139 One reason a surgeon may debate the use of one mesh versus another is the mechanical support the mesh is reported to provide the deficient abdominal wall.139 Mohamed and colleagues139 listed seven important properties of the ideal mesh:

1. Strong enough to withstand physiologic stresses over a long period of time
2. Conform to the abdominal wall
3. Promote strong host tissue ingrowth, which mimics normal tissue healing
4. Resist the formation of bowel adhesions and erosions into visceral structures
5. Not induce allergic reaction or adverse foreign body reactions
6. Resist infection
7. Be noncarcinogenic.

PP mesh has been the standard material against which other materials are compared.140 According to Robinson and colleagues,140 an advantage of PP is that infections can be treated without mandatory removal of the mesh, while other materials such as PTFE may require removal. Biologic mesh materials such as porcine are decellularized living tissues composed of collagen matrix.140 Two theoretical concerns for the use of biologic materials for hernia repair include potential transmission of diseases and the reduction in tensile strength of the mesh.140

### Study Characteristics

General information for the 32 studies addressing Key Question 5 can be found in Table 51 of Appendix C. Nine were conducted in Germany; five in Sweden and/or Finland; four in India; three in Italy; two each in Poland and the United States; and one each in Belgium, Bosnia, Burkina Faso, Estonia, France, Hong Kong, and Pakistan. Twenty-one studies were single-center RCTs; six RCTs reported multiple centers; and four RCTs did not report the type of center. One RCT was conducted in 15 centers in Poland.141

The identified studies assessed various mesh comparisons. Table 9 below lists the comparison types and the number of studies addressing each comparison. The RCTs enrolled between 25 and 600 patients. Twenty-four studies reported patient enrollment dates indicating that studies were conducted between 1996 and 2011.

Table 9 Key Question 5: Mesh comparisons

Comparison | Number of Studies
PP vs. Low-weight PP | 6^142-147^
PP vs. combination materials | 17^141-143,146,148-160^
PP vs. coated PP | 6^142,143,150,161-163^
PP vs. 3D PHS System | 2^164,165^
PP vs. porcine | 2^158,166,167^
PP vs. PP^1^ | 1^160^
PP vs. polyethylene^1^ | 1^168^
PP vs. polyester^1^ | 1^169^
Low weight PP vs. coated PP^1^ | 1^142,143^
Combination materials vs. porcine^1^ | 1^158^
Low weight PP vs. combination materials^1^ | 3^142,143,146^
PP vs. PTFE^1^ | 1^147^
Low weight PP vs. PTFE^1^ | 1^147^
PP vs. PVDF^1^ | 1^170^
Combination materials vs. coated PP^1^ | 3^142,143,150^
Coated PP light vs. coated PP extra-light^1^ | 1^171^
Nylon vs. combination materials^1^ | 1^172^
ePTFE patch vs. ePTFE plus antimicrobial preservative agents patch^1^ | 1^173^

1 No meta-analysis performed for this comparison.

ePTFE = Expanded PTFE; PP = polypropylene; PTFE = polytetrafluoroethylene; PVDF = polyvinylidene fluoride.

Twenty-two studies were conducted at general and nonuniversity hospitals; six were conducted at university hospitals; two included some university hospitals as well as some nonuniversity hospitals; and the remaining two studies did not report the type(s) of hospitals. Eleven of the 32 studies for Key Question 5 reported their source of funding, six of which were supported by funding from Ethicon Endo-Surgery.

Patient enrollment criteria appear in Table 52 (hernia-related criteria), Table 53 (demographic and medical criteria), and Table 54 (other criteria) of Appendix C. Enrollment criteria varied among the 32 studies. The most commonly used hernia-related exclusions were recurrent hernia (15 studies), incarcerated hernia (12 studies), strangulated hernia (10 studies), and bilateral hernia (9 studies). Patients were also excluded if they had an emergency repair (seven studies) or a femoral hernia (six studies), scrotal hernia (four studies), asymptomatic hernia (two studies), and obstructed hernia (two studies).

Thirty studies enrolled patients of a minimum age of 18 years. One study set the minimum age for enrollment at 15 years and a second study set the minimum age at 16 years. Ten studies excluded female patients; two studies each excluded patients with prior general anesthesia, an ASA score >4, pregnant women, and those with infection. Four studies each excluded patients with prior lower abdominal surgery and prior mesh surgery. Lastly, one study each excluded patients with prior treatment, coagulation disorders, advanced carcinoma, and an ASA score >2.

Treatment details appear in Table 55 of Appendix C. Mesh sizes ranged from 4.5 by 10 cm to 15 by 15 cm. The mesh size most frequently reported was 10 by 15 cm. The following table (Table 10) lists various mesh materials, some of which were reported in our literature results for Key Question 5.^140^ Nine studies reported that surgeons had experience in hernia repair. Of these, two mentioned the number of hernia repairs the surgeons had previously performed and one mentioned the number of years of surgeon experience in hernia repair. The surgical procedures performed included 17 studies performing Lichtenstein, 6 performing TEP, 5 performing TAPP, and 4 studies did not specify the surgical procedure.

Table 10 Key Question 5: Types of mesh materials

Material | Trade Name
Polypropylene (PP) | VISILEX™, PerFix™, KUGEL™ Hernia Patch, 3DMAX™ (Davol, Inc.) PROLENE™ (Ethicon Endo-Surgery) SURGIPRO™ (Covidien) Prolite™, Prolite Ultra (Atrium Medical Corp.)
Polyester or Polyethylene-terephthalate | MERSILENE™ (Ethicon Endo-Surgery) Parietex™ (Covidien)
Polytetrafluorethylene (PTFE) | GORE-TEX®, Gore® DUALMESH®, Gore® DUALMESH® Plus, Gore® MYCROMESH® (W.L. Gore & Associates, Inc.) DULEX™, Reconix® (Davol.)
PP/PTFE | Composix®, Composix ® EX, Ventralex® (Davol, Inc.)
PP/Cellulose | PROCEED™ (Ethicon Endo-Surgery)
PP/Seprafilm | SEPRAMESH™, SEPRAMESH™ IP (Davol, Inc.)
PP/Vicryl | VYPRO™, VYPRO™ II (Ethicon Endo-Surgery)
PP/Monocryl (poliglecaprone) | ULTRAPRO™ (Ethicon Endo-Surgery)
Polyester/Collagen Film | Parietex™ Composite (Covidien)
Porcine | Surgisis® (Cook Biotech, Inc.)
Human | AlloDerm® Regenerative Tissue Matrix (LifeCell Corp.)

Reported baseline patient characteristics in the studies included for this Key Question appear in Table 56 of Appendix C. A summary of the most commonly reported baseline characteristics in studies included for Key Questions 2 through 7 appears in section Key Question 2a of this report along with Table 3 (please refer to Key Question 2a for further detail).

### Risk of Bias

The risk-of-bias assessments for the 32 studies appear in Table 57 of Appendix C. Twenty-nine studies were categorized as Moderate risk of bias for all of their reported outcomes. One study was categorized as Low risk of bias for all outcomes,160 and the category for two studies was mixed (Moderate and Low). One study with a mixed category had a Low risk of bias for most outcomes, and Moderate risk of bias for adverse events.174 The second study was categorized as Moderate risk of bias for most outcomes, and Low risk of bias for adverse events and hospital stay.175

Many reasons underlie the Moderate rating for the 33 RCTs. Two of the most common reasons involved concealment of allocation (either not performed or not reported by 19 studies) and the blinding of outcome assessors (either not performed or not reported by 26 studies).

### Findings

The included data for Key Question 5 appears in Table 58 of Appendix C. We have organized this section by type of comparison and outcomes assessed through meta-analysis. We considered seven comparisons to be major:

- Standard PP versus low-weight PP
- PP versus combination materials
- PP versus coated PP
- PP versus 3D PROLENE™ Hernia System (PHS)
- PP versus porcine
- Combination materials versus porcine
- Low-weight PP versus combination materials

#### Polypropylene Versus Low-Weight Polypropylene

##### Hernia Recurrence

We performed a meta-analysis of three studies comparing PP mesh to low-weight PP mesh, (Figure 38), and identified a summary RR of 1.94 (95% CI, 0.35 to 10.78). We defined the MCSD as a three-percentage-point difference between groups, to aid interpretation; we calculated the overall rate of recurrence in the PP mesh group, which was 1.03 percent. Multiplying a 10.78 RR with this rate yielded a corresponding rate of 11.1 percent for low-weight PP mesh group. The difference between these rates is more than 10 percentage points, which is greater than our predefined MCSD. Thus, the evidence is too imprecise to permit a conclusion.

Figure 38 Key Question 5: Polypropylene versus low-weight polypropylene, meta-analysis of recurrence

(I^2^=0%, tau=0)

The figure shows the results of a meta-analysis comparing Standard polypropylene and Low-weight polypropylene on the outcome Recurrence in the context of painful hernia in adults. Points to the left of the midline favor Standard polypropylene, whereas points to the right of the midline favor Low-weight polypropylene. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

##### Quality of Life

Studies did not report this outcome.

##### Patient Satisfaction

Studies did not report this outcome.

##### Long-Term Pain

Three studies reporting long-term pain (>6 months after surgery) as overall VAS scores were included in a meta-analysis (Figure 39) and we found a summary difference in means of 0.15 (95% CI, -0.28 to 0.59 points on a 0–10 scale). The results indicate approximate equivalence between the PP mesh and low-weight PP for the outcome of long-term pain.

Figure 39 Key Question 5: Polypropylene versus low-weight polypropylene, meta-analysis of long-term pain

(I^2^=0%, tau=0)

The figure shows the results of a meta-analysis comparing Standard polypropylene and Low-weight polypropylene on the outcome Long-Term Pain in the context of painful hernia in adults. Points to the left of the midline favor Standard polypropylene, whereas points to the right of the midline favor Low-weight polypropylene. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

##### Adverse Events

We conducted meta-analyses of two types of events: feeling of foreign body (two studies), (Figure 40) and infection (three studies) (Figure 41). We identified a summary OR of 1.23 (95% CI, 0.48 to 3.17) for the outcome of feeling a foreign body and an OR of 1.59 (95% CI, 0.19 to 13.11) for the outcome of infection. These CIs extend beyond our MCSD of 0.8 to 1.25. Thus, the evidence is too imprecise to permit a conclusion.

Figure 40 Key Question 5: Polypropylene versus low-weight polypropylene, meta-analysis of feeling of foreign body

(I^2^=50%, tau=0.49)

The figure shows the results of a meta-analysis comparing Standard polypropylene and Low-weight polypropylene on the outcome Feeling of Foreign Body in the context of painful hernia in adults. Points to the left of the midline favor Standard polypropylene, whereas points to the right of the midline favor Low-weight polypropylene. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

Figure 41 Key Question 5: Polypropylene versus low-weight polypropylene, meta-analysis of infection

(I^2^=0%, tau=0)

The figure shows the results of a meta-analysis comparing Standard polypropylene and Low-weight polypropylene on the outcome Infection in the context of painful hernia in adults. Points to the left of the midline favor Standard polypropylene, whereas points to the right of the midline favor Low-weight polypropylene. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

#### Polypropylene Versus Combination Materials (e.g., Polypropylene, Polyglactin)

##### Hernia Recurrence

We performed a meta-analysis of nine studies comparing PP mesh to combination material mesh (Figure 42), and identified a summary RR of 1.12 (95% CI, 0.59 to 2.10). The median length of follow-up was 1.1 years (range 1 year to 5 years). All nine studies followed the typical patient for at least one year. We defined the MCSD as a three-percentage-point difference between groups, to aid interpretation; we calculated the overall rate of recurrence in the PP mesh group, which was 2.1 percent. Multiplying a 2.10 RR with this rate yielded a corresponding rate of 4.4 percent for the combination material mesh group. The difference between these rates is only 2.31 percent, which is less than our predefined MCSD of three percentage points. This implies approximate equivalence between PP mesh and combination material mesh for this outcome.

Figure 42 Key Question 5: Polypropylene versus combination material, meta-analysis of recurrence

(I^2^=0%, tau=0.00)

The figure shows the results of a meta-analysis comparing Standard polypropylene and Combination material on the outcome Recurrence in the context of painful hernia in adults. Points to the left of the midline favor Standard polypropylene, whereas points to the right of the midline favor Combination material. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

##### Quality of Life

Four studies comparing PP mesh with combination material mesh reported QOL data for various domains of the Short-form 36 (SF-36). Since these studies did not provide an overall QOL score, we were unable to combine the data for meta-analysis. We did provide some discussion of the studies' reported results.

One study assessing development of life quality reported that any differences identified between PP mesh and combination material mesh diminished beyond the 12th postinterventional week.160 A second study, reporting scores for various domains found there was “no detectable difference in any dimension of QOL on the SF-36 between the two treatment groups either before or six months after hernia repair.”157 Another study making the comparison of PP mesh with combination material mesh reported that “the SF-36 results showed few significant differences between groups.”141 The fourth study reported results of QOL assessment at 8 weeks and 1 year. At both time points, the authors found “no clinically relevant difference” between the treatment groups for various domains of the SF-36.^152,153^

##### Patient Satisfaction

Studies did not report this outcome.

##### Long-Term Pain

Three studies reporting long-term pain (>6 months after surgery) as an overall VAS score were included in a meta-analysis (Figure 43). We identified a summary difference in means of 0.09 (95% CI, -0.21 to 0.40). The results indicate approximate equivalence between these treatment groups for the outcome of long-term pain.

Figure 43 Key Question 5: Polypropylene versus combination material, meta-analysis of long-term pain

(I^2^=0%, tau=0)

The figure shows the results of a meta-analysis comparing Standard polypropylene and Combination material on the outcome Long-Term Pain in the context of painful hernia in adults. Points to the left of the midline favor Standard polypropylene, whereas points to the right of the midline favor Combination material. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

##### Adverse Events

We conducted meta-analyses of two types of events: feeling of foreign body (four studies), (Figure 44) and infection (five studies) (Figure 45). The summary OR for feeling of foreign body was 0.91 (95% CI, 0.35 to 2.40) and for infection was 1.29 (95% CI, 0.63 to 2.64). Neither of these outcomes permits a conclusion, due to low precision. The wide CIs for both outcomes include our MCSD of 0.8 to 1.25. Thus, the evidence is too imprecise to permit a conclusion.

Figure 44 Key Question 5: Polypropylene versus combination material, meta-analysis of feeling of foreign body

(I^2^=77%, tau=0.84)

The figure shows the results of a meta-analysis comparing Standard polypropylene and Combination material on the outcome Feeling of Foreign Body in the context of painful hernia in adults. Points to the left of the midline favor Standard polypropylene, whereas points to the right of the midline favor Combination material. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

Figure 45 Key Question 5: Polypropylene versus combination material, meta-analysis of infection

(I^2^=0%, tau=0)

The figure shows the results of a meta-analysis comparing Standard polypropylene and Combination material on the outcome Infection in the context of painful hernia in adults. Points to the left of the midline favor Standard polypropylene, whereas points to the right of the midline favor Combination material. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

#### Polypropylene Versus Coated Polypropylene (e.g., Beta-D-Glucan)

##### Hernia Recurrence

We performed a meta-analysis of three studies comparing PP mesh to coated PP mesh (Figure 46) and identified a summary RR of 1.2 (95% CI, 0.42 to 3.39). We defined the MCSD as a three-percentage-point difference between groups, to aid interpretation; we calculated the overall rate of recurrence in the PP mesh group, which was 2.3 percent. Multiplying a 3.39 RR yielded a corresponding rate of 7.79 percent for the coated PP mesh group. The difference (7.79 percent versus 2.3 percent) is greater than our predefined MCSD of three percentage points. Thus the evidence is too imprecise to permit a conclusion.

Figure 46 Key Question 5: Polypropylene versus coated polypropylene, meta-analysis of recurrence

(I^2^=0%, tau=0)

The figure shows the results of a meta-analysis comparing Standard polypropylene and Coated polypropylene on the outcome Recurrence in the context of painful hernia in adults. Points to the left of the midline favor Standard polypropylene, whereas points to the right of the midline favor Coated polypropylene. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

##### Quality of Life

One study comparing PP mesh with coated PP mesh reported QOL.163 At post-operative days 7 and 30, the authors reported scores on the Short-Form 12 (SF-12). We calculated a difference in means of 0.40 (95% CI, -5.32 to 6.12); the wide CI indicates that the finding is inconclusive.

##### Patient Satisfaction

Studies did not report this outcome.

###### Long-Term Pain

Two studies reporting long-term pain (>6 months after surgery) were included in a meta-analysis (Figure 47). This analysis found a summary OR of 2.84 (95% CI, 0.35 to 23.05). Although the summary OR appears to say patients with the coated PP mesh may experience more long-term pain, the wide CIs for both outcomes include our MCSD of 0.8 to 1.25. Thus, the evidence is too imprecise to permit a conclusion.

Figure 47 Key Question 5: Polypropylene versus coated polypropylene, meta-analysis of long-term pain

(I^2^=73%, tau=1.3)

The figure shows the results of a meta-analysis comparing Standard polypropylene and Coated polypropylene on the outcome Long-Term Pain in the context of painful hernia in adults. Points to the left of the midline favor Standard polypropylene, whereas points to the right of the midline favor Coated polypropylene. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

##### Adverse Events

One study comparing PP mesh with coated PP mesh reported infection rates.162 The authors reported a total of four infections identified in the PP mesh group and two in the coated-PP mesh group.162 We calculated an OR of 1.63 (95% CI, 0.29 to 9.05) for this outcome, and the wide CI means that the evidence is inconclusive.

#### Polypropylene Versus 3D Prolene Hernia System (Two Studies)

##### Hernia Recurrence

We performed a meta-analysis of two studies comparing PP mesh to 3D PHS System (Figure 48), and identified a summary RR of 1.05 (95% CI, 0.07 to 16.47). The studies included for this comparison reported zero events of RC. The evidence is too imprecise to permit a conclusion.

Figure 48 Key Question 5: Polypropylene versus 3D Prolene Hernia System, meta-analysis of recurrence

(I^2^=0%, tau=0)

The figure shows the results of a meta-analysis comparing Standard polypropylene and 3D PHS System on the outcome Recurrence in the context of painful hernia in adults. Points to the left of the midline favor Standard polypropylene, whereas points to the right of the midline favor 3D PHS System. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

##### Quality of Life

Studies did not report this outcome.

##### Patient Satisfaction

Studies did not report this outcome.

##### Long-Term Pain

Studies did not report this outcome.

##### Adverse Events

We conducted meta-analyses of two studies reporting infection (Figure 49). The analysis found a summary OR of 0.51 (95% CI, 0.09 to 2.88), which expands beyond our MCSD of 0.8 to 1.25. Thus, the evidence is too imprecise to permit a conclusion.

Figure 49 Key Question 5: Polypropylene versus 3D Prolene Hernia System, meta-analysis of infection

(I^2^=0%, tau=0)

The figure shows the results of a meta-analysis comparing Standard polypropylene and 3D PHS System on the outcome Infection in the context of painful hernia in adults. Points to the left of the midline favor Standard polypropylene, whereas points to the right of the midline favor 3D PHS System. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

#### Polypropylene Versus Porcine (Two Studies)

##### Hernia Recurrence

We performed a meta-analysis of two studies comparing PP mesh with porcine mesh (Figure 50) and identified a summary RR of 1.93 (95% CI, 0.17 to 22.29). We defined the MCSD as a three-percentage-point difference between groups, to aid interpretation; we calculated the overall rate of recurrence in the PP mesh group, which was 2 percent. Multiplying a 22.294 RR with this rate yielded a corresponding rate of 44.58 percent for the porcine mesh group. The difference between these rates is more than 40 percentage points, which is greater than our predefined MCSD of three percentage points. Thus, the evidence is too imprecise to permit a conclusion.

Figure 50 Key Question 5: Polypropylene versus porcine, meta-analysis of recurrence

(I^2^=0%, tau=0)

The figure shows the results of a meta-analysis comparing Standard polypropylene and Porcine on the outcome Recurrence in the context of painful hernia in adults. Points to the left of the midline favor Standard polypropylene, whereas points to the right of the midline favor Porcine. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

##### Quality of Life

Studies did not report this outcome.

##### Patient Satisfaction

Studies did not report this outcome.

##### Long-Term Pain

One study comparing PP mesh with porcine mesh reported a VAS score for pain at rest and pain on movement at 3 years.166,167 For the outcome of pain at rest, we calculated a difference in means of 0.00 (95% CI, -0.94 to 0.94) and a difference in means of 0.39 (95% CI, -0.55 to 1.33) for the outcome of pain on movement. The results indicate approximate equivalence between the treatment groups for the outcome of long-term pain.

##### Adverse Events

Studies did not report this outcome.

#### Combination Materials Versus Porcine

##### Hernia Recurrence

One study comparing combination material mesh with porcine mesh reporting RC found zero events in each treatment group. We calculated an RR of 1.00 (95% CI, 0.02 to 47.38); the wide CI indicates that the finding is inconclusive.

##### Quality of Life

The study did not report this outcome.

##### Patient Satisfaction

The study did not report this outcome.

##### Long-Term Pain (>6 Months)

The study did not report this outcome.

##### Adverse Events

One study comparing combination material mesh with porcine reported the feeling of stiffness and a foreign body in the groin.158 We calculated an OR of 5.69 (95% CI, 0.94 to 34.46); the wide CI indicates that the finding is inconclusive.

#### Low-Weight Polypropylene Versus Combination Materials

##### Hernia Recurrence

One study comparing low-weight PP mesh with combination material mesh reported RC.146 We calculated an RR of 0.51 (95% CI, 0.05 to 5.54); the wide CI indicates that the finding is inconclusive.

##### Quality of Life

One study comparing low-weight PP mesh with combination material mesh reported the impairment of physical activity at 1 year.142,143 We calculated an OR of 0.49 (95% CI, 0.04 to 5.54); the wide CI indicates that the finding is inconclusive.

##### Patient Satisfaction

The study did not report this outcome.

##### Long-Term Pain (>6 Months)

One study comparing low-weight PP mesh with combination material mesh reported overall VAS scores for the outcome of long-term pain.146 We calculated a difference in means of 0.00 (95% CI, -0.65 to 0.65). This implies approximate equivalence between low-weight PP mesh and combination material mesh.

A second study reported the number of patients experiencing pain in the inguinal region at 1 year.142,143 We calculated an OR of 1.0 (95% CI, 0.25 to 4.07); the wide CI indicates that the finding is inconclusive.

##### Adverse Events

One study comparing low-weight PP mesh with combination material mesh reported infection and the feeling of a foreign body.146 We calculated an OR of 1.73 (95% CI, 0.54 to 5.55) for the outcome of feeling a foreign body. For the outcome of infection, the calculated OR is 0.35 (95% CI, 0.01 to 8.64). Both findings are inconclusive.

### Applicability

Thirty-two studies are included for review for Key Question 5. We evaluated these studies to identify factors that might affect the applicability of the evidence. As described in the Methods section, the goal of the evaluation is to draw stakeholders' attention to potential applicability issues embedded in the evidence rather than generating a rating or score for the applicability.

The 32 studies compared different mesh products used in hernia repair. See Table 55 of Appendix C for a detailed description of the mesh products compared in the studies. For Key Question 5, we summarized the evidence for each comparison of mesh products.

In 22 of the 32 studies reviewed for Key Question 5, the surgeries were performed 5 or more years ago (before 2006). The evidence may not necessarily reflect the comparative performance of the state-of-the-art mesh products that are currently used in clinical practice.

The majority of the 32 studies reviewed did not report data on surgeons' prior experiences with the hernia repair procedures or the mesh products being used. For the studies that did report such data, the meaning of “experience” was not explicitly defined (e.g., by the number of prior cases or years of practice). Given the data reported, we were unable to judge what implication surgeons' experience may have in the applicability of the evidence. Table 55 of Appendix C provides additional detail on the surgical procedures compared in the studies, including data on surgeons' prior experience.

Patient enrollment criteria and reported baseline characteristics varied significantly across the 32 studies reviewed. The most commonly used exclusions were recurrent hernia (15 studies), incarcerated hernia (12 studies), bilateral hernia (9 studies), strangulated hernia (10 studies), hernia requiring emergency repair (7 studies), and femoral hernia (6 studies). From the reported data, we did not identify any general pattern in the patient population enrolled that may have a significant impact on the applicability of the overall evidence. Detailed patient enrollment criteria and baseline characteristics of these studies are provided in Table 52 and Table 56 of Appendix C.

Except for three studies, all other 29 studies were performed outside of the United States, primarily in European countries. The differences in health care systems and practice patterns between the United States and other regions might have an impact on the applicability of the evidence from the perspectives of U.S. stakeholders. The clinical setting varied significantly across the studies, ranging from outpatient surgical clinics, community hospitals, and academic medical centers. Based on the data reported, it is unclear how the clinical settings of the studies might have affected the applicability of the evidence. Detailed information on geographic and clinical settings of the studies is provided in Table 51 of Appendix C.

### Summary of Key Question 5

A summary of the comparisons and outcomes we examined for this Key Question can be found in Table 11 below. Of the 11 outcomes, the evidence was sufficient to permit a conclusion for 2 outcomes assessed by the various comparisons of mesh types:

- Long-term pain (>6 months) for the comparisons of PP mesh versus low-weight PP mesh and PP mesh versus porcine indicated approximate equivalence.
- Recurrence for the comparison of PP mesh versus combination material mesh indicated approximate equivalence.

Table 11 Key Question 5: Strength of evidence ratings

Comparison | Outcome | # Studies | Overall Risk of Bias | Consistency | Directness | Precision | Evidence Favors | SOE Rating
PP vs. low-weight PP | Recurrence | 3 | MOD | C | D | I (RR 0.35 to 10.78) | ? | INSUFF
PP vs. low-weight PP | Long term pain (≥6 months) (0–10 scale) | 3 | MOD | I | D | P Diff. in scores 0.43 (CI -0.28 to 0.59) | EQ | LOW
PP vs. low-weight PP | Feeling of foreign body | 2 | MOD | C | D | I (OR 0.48 to 3.17) | ? | INSUFF^†^
PP vs. low-weight PP | Infection | 3 | MOD | C | D | I (OR 0.19 to 13.11) | ? | INSUFF
PP vs. combination materials | Recurrence | 9 | MOD | C | D | P RR 1.12 (CI 0.59 to 2.10) | EQ | MOD
PP vs. combination materials | Long term pain (≥6 months) (0–10 scale) VAS | 3 | MOD | I | D | P (Diff -0.21 to 0.40) | ? | INSUFF^†^
PP vs. combination materials | Feeling of foreign body | 4 | MOD | C | D | I (OR 0.35 to 2.40) | ? | INSUFF^†^
PP vs. combination materials | Infection | 5 | MOD | C | D | I (OR 0.63 to 2.64) | ? | INSUFF^†^
PP vs. coated PP | Recurrence | 3 | MOD | C | D | I (RR 0.42 to 3.39) | ? | INSUFF
PP vs. coated PP | Quality of Life | 1 | MOD | U | D | I (Diff -5.3 to 6.1) | ? | INSUFF^†^
PP vs. coated PP | Long term pain (≥6 months) | 2 | MOD | C | D | I (OR 0.35 to 23.05) | ? | INSUFF^†^
PP vs. coated PP | Infection | 1 | MOD | U | D | I (OR 0.29 to 9.05) | ? | INSUFF^†^
PP vs. 3D PHS | Recurrence | 2 | MOD | C | D | I (RR 0.07 to 16.47) | ? | INSUFF
PP vs. 3D PHS | Infection | 2 | MOD | C | D | I (OR 0.09 to 2.88) | ? | INSUFF
PP vs. porcine | Recurrence | 2 | MOD | C | D | I (RR 0.17 to 22.29) | ? | INSUFF
PP vs. porcine | Long term pain (≥6 months) VAS at rest (0–10 scale) | 1 | MOD | U | D | P Diff in scores 0 (CI -0.94 to 0.94) | EQ | LOW
PP vs. porcine | Long term pain (≥6 months) VAS on movement (0–10 scale) | 1 | MOD | U | D | P Diff in scores 0.39 (CI -0.55 to 1.33) | EQ | LOW
Combination materials vs. porcine | Recurrence | 1 | MOD | U | D | I (RR 0.02 to 47.38) | ? | INSUFF
Combination materials vs. porcine | Feeling of foreign body | 1 | MOD | U | D | I (OR 0.94 to 34.46) | ? | INSUFF
Low-weight PP vs. combination materials | Recurrence | 1 | MOD | U | D | I (RR 0.05 to 5.54) | ? | INSUFF^†^
Low-weight PP vs. combination materials | Quality of Life | 1 | MOD | U | D | I (OR 0.04 to 5.54) | ? | INSUFF^†^
Low-weight PP vs. combination materials | Long-term pain (≥6 months) (0–10 scale) | 1 | MOD | U | D | P (Diff -0.65 to 0.65) | ? | INSUFF^†^
Low-weight PP vs. combination materials | Long-term pain (≥6 months) in inguinal region | 1 | MOD | U | D | I (OR 0.25 to 4.07) | ? | INSUFF^†^
Low-weight PP vs. combination materials | Feeling of foreign body | 1 | MOD | U | D | I (OR 0.54 to 5.55) | ? | INSUFF^†^
Low-weight PP vs. combination materials | Infection | 1 | MOD | U | D | I (OR 0.01 to 8.64) | ? | INSUFF^†^

Diff = difference, OR = odds ratio, RR = relative risk, VAS = visual analog scale

For consistency, C = consistent, I = inconsistent, U = unknown consistency because there was only one study.

For directness, D = direct, I = indirect.

For precision, I = imprecise, P = precise.

For the column labeled “Evidence favors,” ? denotes inconclusive evidence, and EQ denotes approximate equivalence.

For the column labeled SOE rating, SOE = strength of evidence, INSUFF = insufficient,

* indicates that the SOE was upgraded due to a large magnitude of effect. and

† indicates that the SOE was downgraded due to publication bias or selective outcome reporting.

Our ratings of the SOE for these outcomes also appear in the table. Studies were typically a Moderate risk of bias (see Risk of Bias section) and considered direct. The SOE ratings for comparisons with meta-analytic results ranged from Insufficient to Moderate. For the outcome of recurrence, the evidence indicated a nonsubstantial difference between treatment groups for the comparison of PP mesh versus combination material mesh. The SOE for this comparison was Moderate. The comparisons of PP versus low-weight PP and PP versus porcine received a low SOE rating for the outcome of long-term pain. For this outcome, two other comparisons initially received a low SOE rating: PP versus combination materials; and low-weight PP versus combination materials. However, the SOE rating was downgraded to insufficient because less than one-third of the studies included for these comparisons reported the outcome of long-term pain, indicating a possibility of selective outcome reporting. Some imprecision was found for several comparisons and the analyzed outcomes of interest that precluded conclusions. For the outcome of feeling of foreign body, the finding was inconclusive for the following comparisons: PP mesh versus low-weight PP mesh, PP mesh versus combination material mesh, combination materials versus porcine, and low-weight PP versus combination materials. The outcome of infection was inconclusive for several comparisons: PP mesh versus low-weight mesh, PP mesh versus combination material mesh, PP mesh versus coated PP mesh, PP mesh versus 3D PHS, and low-weight PP versus combination materials. For the outcome of recurrence the finding was inconclusive for the comparisons of PP mesh versus low-weight PP, PP mesh versus coated PP mesh, PP versus 3D PHS, PP versus porcine, combination materials versus porcine, and low-weight PP versus combination materials. For the outcome of long-term pain the finding was inconclusive for the PP mesh versus coated PP mesh comparison.

Questions about the relative importance of these outcomes need to be considered carefully. Some may believe the advantages of various “lighter weight,” “partially absorbable” mesh types outweigh the disadvantages of the typical mesh material such as PP mesh.

FDA has a Web page devoted specifically to the topic of surgical mesh in the context of hernia repair.26 It states:

“Hundreds of thousands of hernia repair operations are performed each year both with and without surgical mesh, and patients generally recover quickly and do well after surgery. However, FDA has received reports of complications associated with the mesh. The complications include adverse reactions to the mesh, adhesions (when the loops of the intestines adhere to each other or the mesh), and injuries to nearby organs, nerves or blood vessels. Other complications of hernia repair can occur with or without the mesh, including infection, chronic pain and RC. Most of the complications reported to us so far have been associated with mesh products that have been recalled and are no longer on the market.”26

We searched the FDA Web site and identified the following official product calls:

- The first, involving Bard Composix Kugel Extra Large Oval Patches, was initiated in December 2005 and was expanded in March 2006 and also in January 2007.^27^ The Class I recall applies to this specific product and only to meshes manufactured before October 2005. The stated reason for the recall on the FDA Web site was “The ‘memory recoil ring’ that opens the Bard® Composix® Kugel® Mesh Patch can break under the stress of placement of the large sized products in the intra-abdominal (inside the belly area) space.”
- The second product recall was for 14 lot numbers of the XenMatrix Surgical Graft. This was a Class I recall initiated in January 2011 and applies only to the products distributed between July 1, 2010, and October 31, 2010. The FDA Web site stated that the recall was because “testing cannot confirm that all units of XenMatrix Surgical Graft are within FDA requirements for endotoxin levels. Several lots have been found to have elevated endotoxin levels.”28
- The third product recall was for 15 lot numbers of the Bard Flat Mesh; this Class I recall was initiated in March 2010 and applies to products distributed between October 21, 2008, and October 27, 2009. The FDA Web site stated that the recall was because “the product was deemed a counterfeit. The product does not meet manufacturer's specifications.”29

Three non-English studies might have met the inclusion criteria for this Key Question if we had not required that studies be published in English.176-178 Two of these were stated to be randomized trials, and we are unsure whether the fourth study was randomized; however, it was a comparison study. We summarize the results as follows:

- One study176 comparing Bard Corp. meshes with Auto Suture Co. hernia link plug and netted patch found that after 12 months of followup, a total of 42 patients reported having a foreign body sensation, 47 patients experienced other complications, and 4 infections were recorded. The authors concluded that there was no statistically significant difference between the two treatment groups and that these particular meshes had similar effectiveness. These results are consistent with the conclusions of our review. Our results indicated an inconclusive finding for the outcome of feeling of foreign body and infection rates for all comparisons
- One RCT177 comparing a rigid PP mesh with a softer PP mesh found that patients with the rigid PP mesh reported testicular sensitivity to touch, pain upon ejaculation, and pulling sensation during urination. These complications are stated to be reported less frequently in patients with the softer PP mesh group. These individual domains of pain were not discussed for this report; instead we assessed overall pain scores. Our results indicated approximate equivalence for the outcome of long-term pain (greater than 6 months) for the following comparisons: PP versus low-weight PP, PP versus combination material, PP mesh versus porcine, and low-weight PP versus combination material mesh.
- Another RCT178 comparing PP mesh with expanded PTFE mesh and a control group found there was no difference in VAS pain between the two meshes, as well as no significant difference of incidence of infections and other adverse events. The authors concluded that both of the included mesh types were safe and effective with a low recurrence rate. Our results indicated approximate equivalence for the outcome of long-term pain (>6 months) for the following comparisons: PP versus low-weight PP, PP versus combination material, PP mesh versus porcine, and low-weight PP versus combination material mesh. For the outcome of recurrence, our results indicated approximate equivalence for the comparison of PP mesh versus comparison material mesh.

## Key Question 6 Do different mesh-fixation methods (e.g., no fixation, sutures, glue) differ in patient-oriented effectiveness outcomes and/or adverse events?

### Study Characteristics

General information about the 23 studies included for Key Question 6 can be found in Table 59 of Appendix C. Four were conducted in Italy; three each in Australia and the United States; two each in Finland, India, Spain, and Switzerland; and one each in China, Germany, Poland, Sweden, and the United Kingdom. Nineteen studies were single-center RCTs, two RCTs were conducted in at least two centers, one RCT was conducted in three centers, and one RCT did not report the type of center.

The identified studies assessed various mesh fixation comparisons. Table 12 below lists the comparison types and the number of studies addressing each comparison. Twenty-two RCTs enrolled between 27 and 600 patients, and a Swedish registry included 142,578 hernias. Nineteen studies reported patient enrollment dates between 1996 and 2011, and one study did not report the dates of enrollment.179

Table 12 Key Question 6: Fixation methods comparisons

Comparison | Number of Studies
Tacks or staples vs. no fixation | 7^180-186^
Fibrin glue vs. staples | 5^179,187-190^
Sutures vs. tacks | 3^191-193^
Sutures vs. glue | 7^194-200^
Comparing different types of staples (e.g., EndoANCHOR™ staples vs. EMS™ staples, Ethicon Endo-Surgery) | 2^190,193^
Absorbable sutures (short or long term) vs. nonabsorbable | 1^201^
Glue vs. no fixation | 1^202^

Seventeen studies were conducted at general and nonuniversity hospitals, one study was conducted at a university hospital, and five studies did not report the type(s) of hospitals. Three studies reported their funding source. One study received funding from a public foundation in Spain,188 one study received funding from a hospital group in China,187 and the Swedish registry received funding from various sources (e.g., Sweden's National board of Health and Welfare).125

Patient enrollment criteria appear in Table 60 (hernia-related criteria), Table 61 (demographic and medical criteria), and Table 62 (other criteria) of Appendix C. Enrollment criteria varied among the 23 studies. The most commonly used hernia-related exclusions were recurrent hernia (12 studies), incarcerated hernia (7 studies), bilateral (5 studies), and strangulated hernia (6 studies). Others were emergency hernia (eight studies), femoral hernia (five studies), giant hernia (two studies), scrotal hernia (two studies), and giant scrotal hernia (two studies).

Twenty studies enrolled patients of a minimum age of 18 years, two studies enrolled patients of a minimum age of 15 years, and one study had a minimum enrollment age of 16 years. Five studies excluded female patients, four studies excluded those with prior general anesthesia, two studies excluded patients with ASA scores of >4, three excluded patients with prior abdominal surgery, and two studies excluded patients with prior infections. The following exclusions were reported in one study each: prior mesh surgery and coagulation disorders.

Treatment details appear in Table 63 of Appendix C. Various manufacturers of mesh fixation material were represented in the included studies. Some of the fixation materials identified included Vivostat®, Autosuture™, ENDOPATH®, and Indermil® Tissue Adhesive. Eleven studies reported that surgeons had experience in hernia repair. One study reported that team members performed more than 4,000 TEP repairs between 1994 and 2008.^186^ Another study reports that the surgeon had previously performed 97 primary open inguinal hernia repairs.200 The surgical procedures reported in the studies varied. Lichtenstein method was reported in eight studies, TEP in six studies, and TAPP in six studies; three studies did not specify the surgical procedure. With open surgical procedures, mesh materials are always fixated, while fixation is optional with laparoscopic procedures.

All reported baseline patient characteristics in the studies included for this Key Question appear in Table 64 in Appendix C. A summary of the most commonly reported baseline characteristics in studies included for Key Questions 2 to 7 appears in section Key Question 2a along with Table 3 (please refer to Key Question 2a for further detail).

### Risk of Bias

The risk-of-bias assessments for the 23 studies can be found in Table 65 of Appendix C. Twenty studies were categorized as Moderate risk of bias for all of their reported outcomes. One study was categorized as Low risk of bias for all outcomes193 except testicular swelling and evidence of atrophy; these outcomes were categorized as Moderate risk of bias. Another study was categorized as Low risk of bias for all outcomes except for return to work, which was categorized as Moderate risk of bias.184 One study received a Low risk of bias category for the outcomes of urinary retention, seroma/hematoma, infection, and recurrence.200 All other outcomes were categorized as moderate. Lastly, one study was categorized as Moderate risk of bias for most outcomes,189 but the outcomes of recurrence, postoperative hospital stay, recovery time to normal activity, and adverse events (e.g., hematoma, infection) were categorized as Low risk of bias.

Many reasons underlie the Moderate rating for the 23 RCTs. Two of the most common reasons involved concealment of allocation (either not performed or not reported by 13 studies) and the blinding of outcome assessors (either not performed or not reported by more than 14 studies).

### Findings

All included data for this Key Question appear in Table 66 of Appendix C. We have organized this section by type of comparison, followed by outcomes assessed through meta-analysis. We considered the following five comparisons to be major:

- Tacks or staples versus no fixation
- Fibrin glue versus staples
- Suture versus tacks
- Suture versus glue
- Absorbable sutures versus nonabsorbable sutures

#### Tacks or Staples Versus No Fixation

##### Hernia Recurrence

We performed a meta-analysis of four studies comparing tacks or staples with no fixation method (Figure 51) and identified a summary RR of 0.50 (95% CI, 0.08 to 3.01). The median follow-up was 2 years (range 1 to 2 years). All four studies followed the typical patient for at least one year. We defined the MCSD as a three-percentage-point difference between groups, to aid interpretation; we calculated the overall rate of recurrence in the group with no fixation, which was 1.4 percent. Multiplying a 3.01 RR with this rate yielded a corresponding rate of 4.21 percent for the tacks or staples group. The difference between these rates is 2.81 percentage points, which is less than our predefined MCSD of three percentage points. This implies approximate equivalence in recurrence rates between the two groups.

Figure 51 Key Question 6: Tacks or staples versus no fixation, meta-analysis of recurrence

(I^2^=0%, tau=0)

The figure shows the results of a meta-analysis comparing Tacks or Staples and No fixation on the outcome Recurrence in the context of painful hernia in adults. Points to the left of the midline favor Tacks or Staples, whereas points to the right of the midline favor No fixation. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

##### Quality of Life

Studies did not report this outcome.

##### Patient Satisfaction

Studies did not report this outcome.

##### Long-Term Pain

One study comparing tacks or staples versus no fixation reported long-term pain.186 We calculated a difference in means of 0.03 (95% CI, -0.76 to 0.82) for this outcome. This implies approximate equivalence between tacks or staples and no fixation for the outcome of long-term pain.

##### Adverse Events

One study comparing tacks or staples with no fixation method reported two adverse events, bleeding and infection.182 Eleven patients in the tacks or staples group and 10 patients in the no fixation group experienced bleeding. We calculated an OR of 1.12 (95% CI, 0.45 to 2.78) for the outcome of bleeding. We calculated an OR of 3.036 (95% CI, 0.12 to 75.57) for the outcome of infection. The wide CIs indicate the evidence is inconclusive.

#### Fibrin Glue Versus Staples

##### Hernia Recurrence

We performed a meta-analysis of three studies comparing fibrin glue with staples (Figure 52) and identified a summary RR of 1.237 (95% CI, 0.31 to 4.96). We defined the MCSD as a three-percentage-point difference between groups, to aid interpretation; we calculated the overall rate of recurrence in the fibrin glue group, which was 2.4 percent. Multiplying a 4.96 RR with this rate yielded a corresponding rate of 12 percent for the staples group. The difference between these rates is 9.6 percent, which is more than our predefined MCSD of three percentage points, indicating the evidence is inconclusive.

Figure 52 Key Question 6: Fibrin glue versus staples, meta-analysis of recurrence

(I^2^=0%, tau=0)

The figure shows the results of a meta-analysis comparing Fibrin Glue and Staples on the outcome Recurrence in the context of painful hernia in adults. Points to the left of the midline favor Fibrin Glue, whereas points to the right of the midline favor Staples. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

##### Quality of Life

One study comparing fibrin glue with staples reported QOL.189 We calculated a difference in means of 0.00 (95% CI, -0.09 to 0.09) for this outcome. This implies approximate equivalence between fibrin glue and staples for the outcome of QOL.

##### Patient Satisfaction

Studies did not report this outcome.

##### Long-Term Pain

Three studies reporting long-term pain (>6 months after surgery) as an overall score on the VAS were included in a meta-analysis (Figure 53). This analysis found a difference in means of -0.47 (95% CI, -0.68 to -0.27), indicating a lower rate of long-term pain with glue fixation than staple fixation. This indicates a clinically significant difference in rates.

Figure 53 Key Question 6: Fibrin glue versus staples, meta-analysis of long-term pain

(I^2^=0%, tau=0)

The figure shows the results of a meta-analysis comparing Fibrin Glue and Staples on the outcome Long-Term Pain in the context of painful hernia in adults. Points to the left of the midline favor Fibrin Glue, whereas points to the right of the midline favor Staples. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

##### Adverse Events

Studies did not report this outcome.

#### Sutures Versus Tacks

##### Hernia Recurrence

We performed a meta-analysis of two studies comparing sutures with tacks (Figure 54) and identified a summary RR of 1.98 (95% CI, 0.16 to 22.21). We defined the MCSD as a three-percentage-point difference between groups, to aid interpretation; we calculated the overall rate of recurrence in the sutures group, which was 0.69 percent. Multiplying a 22.21 RR with this rate yielded a corresponding rate of 15.3 percent for the tacks group. The difference between these rates is over 14 percentage points, which is greater than our predefined MCSD. Thus, the evidence is too imprecise to permit a conclusion.

Figure 54 Key Question 6: Sutures versus tacks, meta-analysis of recurrence

(I^2^=0%, tau=0)

The figure shows the results of a meta-analysis comparing Sutures and Tacks on the outcome Recurrence in the context of painful hernia in adults. Points to the left of the midline favor Sutures, whereas points to the right of the midline favor Tacks. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

##### Quality of Life

Studies did not report this outcome.

##### Patient Satisfaction

Studies did not report this outcome.

##### Long-Term Pain

Studies did not report this outcome.

##### Adverse Events

Studies did not report this outcome.

#### Sutures Versus Glue

##### Hernia Recurrence

We performed a meta-analysis of four studies comparing sutures with glue (Figure 55) and identified a summary RR of 0.71 (95% CI, 0.30 to 1.71). The median follow-up was 1.7 years (range 6 months to 5 years). One study followed the typical patient for <1 year, and three studies followed the typical patient for 1 to 5 years. We defined the MCSD as a three-percentage-point difference between groups, to aid interpretation; we calculated the overall rate of recurrence in the sutures group, which was 2.6 percent. Multiplying a 1.71 RR with this rate yielded a corresponding rate of 4.45 percent for the glue group. The difference between these rates is 1.85 percentage points and indicates approximate equivalence.

Figure 55 Key Question 6: Sutures versus glue, meta-analysis of recurrence

(I^2^=0%, tau=0.00)

The figure shows the results of a meta-analysis comparing Sutures and Glue on the outcome Recurrence in the context of painful hernia in adults. Points to the left of the midline favor Sutures, whereas points to the right of the midline favor Glue. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

###### Quality of Life

Studies did not report this outcome.

##### Patient Satisfaction

One study comparing sutures with glue reported patient SFN. We calculated a difference in means of -0.24 (95% CI, -0.58 to 0.10). This implies approximate equivalence for the outcome of patient SFN when comparing suture fixation and glue fixation.

##### Long-Term Pain

Three studies comparing sutures with glue reported long-term pain. We calculated a difference in means of 0.10 (95% CI, -0.07 to 0.27); the wide CI implies approximate equivalence of long-term pain when comparing sutures with glue fixation (Figure 56).

Figure 56 Key Question 6: Sutures versus glue, meta-analysis of long-term pain

(I^2^=5.76%, tau=0.00)

The figure shows the results of a meta-analysis comparing Sutures and Glue on the outcome Long-Term Pain in the context of painful hernia in adults. Points to the left of the midline favor Sutures, whereas points to the right of the midline favor Glue. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

One study reported the number of patients who were pain-free when walking at 1 year and the number of patients reporting scrotal or testicular pain at 1 year.199 We calculated an OR of 0.32 (95% CI, 0.03 to 3.15) for the outcome of pain-free walking and an OR of 2.04 (95% CI, 0.18 to 22.78) for scrotal or testicular pain. The wide CIs include our MCSD of 0.8 to 1.25. Thus, the evidence for these outcomes is too imprecise to permit a conclusion.

##### Adverse Events

We conducted meta-analyses of infection for four studies comparing sutures with glue (Figure 57). Our analysis found a summary OR of 0.58 (95% CI, 0.16 to 2.06). The wide CI includes our pre-determined MCSD of 0.8 to 1.25. Thus, the evidence implies approximate equivalence.

Figure 57 Key Question 6: Sutures versus glue, meta-analysis of infection

(I^2^=0%, tau=0)

The figure shows the results of a meta-analysis comparing Sutures and Glue on the outcome Infection in the context of painful hernia in adults. Points to the left of the midline favor Sutures, whereas points to the right of the midline favor Glue. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

One study reported the feeling of foreign body at 1 year for the comparison of sutures versus glue.199 We calculated an OR of 0.81 (95% CI, 0.47 to 1.39); the wide CI includes our MCSD of 0.8 to 1.25. Thus, the evidence is too imprecise to permit a conclusion.

#### Absorbable Sutures Versus Nonabsorbable Sutures

##### Hernia Recurrence

One study comparing absorbable sutures with nonabsorbable sutures reported one event of RC in each treatment group.201 We calculated an RR of 1.00 (95% CI, 0.06 to 15.72); the wide CI indicates that the evidence is insufficient for a conclusion.

##### Quality of Life

The study did not report this outcome.

##### Patient Satisfaction

One study comparing absorbable sutures with nonabsorbable sutures reported patient SFN.201 At mean follow-up of 2.1 years, 73 (90 percent) patients in the absorbable suture group and 77 (95 percent) patients in the nonabsorbable suture group reported being satisfied with the operation. We calculated an OR of 0.47 (95% CI, 0.14 to 1.64). The wide CI includes our MCSD of 0.8 to 1.25. Thus, the evidence is too imprecise to permit a conclusion.

##### Long-Term Pain

One study comparing absorbable sutures with nonabsorbable sutures reported long-term pain.201 At a mean followup of 2.1 years, 21 (26 percent) patients in the absorbable sutures group reported having pain within the past month, and 19 (23.4 percent) patients in the nonabsorbable group reported the same. We calculated an OR of 1.14 (95% CI, 0.56 to 2.33). The wide CI includes our MCSD of 0.8 to 1.25. Thus, the evidence is too imprecise to permit a conclusion.

##### Adverse Events

One study comparing absorbable sutures with nonabsorbable sutures reported infection.201 We calculated an OR of 3.04 (95% CI, 0.12 to 75.67); the wide CI indicates that the evidence is inconclusive.

### Applicability

Twenty-three studies are included for review for Key Question 6. As described in the Methods section, the goal of the evaluation is to raise stakeholders' attention to potential applicability issues embedded in the evidence rather than generating a rating or score for the applicability.

The 23 studies reviewed for Key Question 5 compared different mesh fixation methods. Table 63 of Appendix C provides a detailed description of the fixation methods being compared in the studies. For Key Question 6, we summarized the evidence by different comparison of mesh fixation methods. In the vast majority of these studies, the surgeries were performed in the 1990s or early 2000s. The evidence may not necessarily reflect the comparative performance of the state-of-the-art mesh fixation methods that are currently used in clinical practice.

Ten studies reported that surgeons had experience in hernia repair. Eight of the studies reported having used experienced surgeons, and two specifically defined the level and meaning of experience (e.g., by the number of prior cases or years of practice). One study reported having used first- or second-year residents. The remaining 12 studies did not report surgeons' prior experiences with hernia repair. Given the data reported, we were unable to judge what implication surgeons' experience may have in the applicability of the evidence. Table 63 of Appendix C provides additional detail on the surgical procedures compared in the studies, including data on surgeons' experiences.

Patient enrollment criteria and reported baseline characteristics varied significantly across the 23 studies reviewed. From the reported data, we did not identify any general pattern in the patient population enrolled that may have a significant impact on the applicability of the overall evidence. Detailed patient enrollment criteria and baseline characteristics of these studies are provided in Table 60 and Table 64 of Appendix C.

Except for three studies,180,185,191 all other studies were performed outside of the United States, primarily in European countries. The differences in health care systems and practice patterns between the U.S. and other regions might have an impact on the applicability of the evidence from the perspectives of the U.S. stakeholders. The clinical setting varied significantly across the studies, ranging from outpatient surgical clinics, an infirmary, community hospitals, and academic medical centers. Based on the data reported, it is unclear how the clinical settings of the studies might have affected the applicability of the evidence. Detailed information on geographic and clinical settings of the six studies is provided in Table 59 in Appendix C.

### Summary of Key Question 6

A summary of the comparisons and outcomes we examined for Key Question 6 can be found in Table 13 below. Of the 11 outcomes, the evidence was sufficient to permit a conclusion for two outcomes assessed by the various comparisons of mesh fixation types:

- Long-term pain (>6 months) for the comparison of fibrin glue with staples favors fibrin glue
- Long-term pain (>6 months) for the comparison of sutures versus glue indicated approximate equivalence
- Recurrence for the comparisons of tacks or staples versus no fixation, and sutures versus glue indicated approximate equivalence

Table 13 Key Question 6: Strength of evidence ratings

Comparison | Outcome | # Studies | Overall Risk of Bias | Consistency | Directness | Precision | Evidence Favors | SOE Rating
Tacks or staples vs. no fixation | Recurrence | 4 | MOD | C | D | P RR 0.50 (CI 0.08 to 3.01) | EQ | MOD
Tacks or staples vs. no fixation | Long-term pain (≥6 months) | 1 | MOD | U | D | I (Diff -0.76 to 0.82) | ? | INSUFF^†^
Tacks or staples vs. no fixation | Bleeding | 1 | MOD | U | D | I (OR 0.45 to 2.78) | ? | INSUFF^†^
Tacks or staples vs. no fixation | Infection | 1 | MOD | U | D | I (OR 0.12 to 75.57) | ? | INSUFF^†^
Fibrin glue vs. staples | Recurrence | 3 | MOD | C | D | I (RR 0.31 to 4.96) | ? | INSUFF
Fibrin glue vs. staples | Quality of life | 1 | MOD | U | D | I (Diff -0.09 to 0.09) | ? | INSUFF^†^
Fibrin glue vs. staples | Long term pain (≥6 months) (0-10 scale) | 3 | MOD | C | D | P Diff -0.47 (CI -0.68 to -0.27) | Favors fibrin glue | MOD
Sutures vs. tacks | Recurrence | 2 | MOD | C | D | I (RR 0.16 to 22.21) | ? | INSUFF
Sutures vs. glue | Recurrence | 4 | MOD | C | D | P RR 0.71 (CI 0.30 to 1.71) | EQ | MOD
Sutures vs. glue | Patient Satisfaction | 1 | MOD | U | D | I (Diff -0.58 to 0.10) | ? | INSUFF^†^
Sutures vs. glue | Long term pain (≥6 months) (0-10 scale) | 3 | MOD | I | D | P Diff 0.10 (CI -0.07 to 0.27) | EQ | LOW
Sutures vs. glue | Long-term pain (≥6 months) pain-free walking | 1 | MOD | U | D | I (OR 0.03 to 3.15) | ? | INSUFF^†^
Sutures vs. glue | Long-term pain (≥6 months) scrotal or testicular pain | 1 | MOD | U | D | I (OR 0.18 to 22.78) | ? | INSUFF^†^
Sutures vs. glue | Feeling of foreign body | 1 | MOD | U | D | I (OR 0.47 to 1.39) | ? | INSUFF^†^
Sutures vs. glue | Infection | 4 | MOD | C | D | I (RR 0.16 to 2.06) | ? | INSUFF
Absorbable sutures vs. nonresorbable sutures | Recurrence | 1 | MOD | U | D | I (OR 0.06 to 15.72) | ? | INSUFF
Absorbable sutures vs. nonresorbable sutures | Long term pain (≥6 months) (0-10 scale) VAS | 1 | MOD | U | D | I (OR 0.56 to 2.33) | ? | INSUFF
Absorbable sutures vs. nonresorbable sutures | Satisfaction | 1 | MOD | U | D | I (OR 0.14 to 1.64) | ? | INSUFF
Absorbable sutures vs. nonresorbable sutures | Infection | 1 | MOD | U | D | I (OR 0.12 to 75.67) | ? | INSUFF

Diff = difference, OR = odds ratio, RR = relative risk, VAS = visual analog scale

For consistency, C = consistent, I = inconsistent, U = unknown consistency because there was only one study.

For directness, D = direct and I = indirect.

For precision, I = imprecise, P = precise.

For the column labeled “Evidence favors,” ? denotes inconclusive evidence, and EQ denotes approximate equivalence.

For the column labeled SOE rating, SOE = strength of evidence, INSUFF = insufficient,

* indicates that the SOE was upgraded due to a large magnitude of effect. and

† indicates that the SOE was downgraded due to publication bias or selective outcome reporting.

Our ratings of the SOE for these outcomes also appear in the table. Studies were typically a Moderate risk of bias (see Risk of Bias section above). Our SOE ratings for comparisons with meta-analytic results ranged from Low to Moderate. For the outcome of long-term pain, the comparison of fibrin glue versus staples received a Moderate SOE rating. The comparisons of tacks or staples versus no fixation, fibrin glue versus staples, and sutures versus glue received a Moderate SOE rating for the outcome of recurrence. Imprecision was identified for several comparisons and the analyzed outcomes, precluding any conclusions.

Questions about the relative importance of these outcomes need to be considered carefully. Some may believe the advantages of various mesh fixation methods that prevent significant tension (e.g., glue) may outweigh the disadvantages of other types of fixation methods (e.g., staples).

One non-English study might have met the inclusion criteria for this Key Question if we had not required that studies be published in English.203 This study is an RCT that compared resorbable suture material with nonabsorbable suture material. The authors report that differences in the recurrence rates following the use of these fixation methods were not statistically significant. Our results indicate approximate equivalence for the outcome of RC for the comparison of fibrin glue with staples.

## Key Question 7 For each type of laparoscopic mesh repair, what is the association between surgical experience and hernia recurrence?

### Study Characteristics

Thirty-two studies were included for this question (Table 14). Sixteen involved only TEP, 12 involved only TAPP, one reported separate data on TEP and TAPP, and three provided combined data on TAPP and TEP. Totals per procedure were 17 TEP, 13 TAPP, and 3 combined TEP/TAPP. Within each of these subgroups, most studies reported data by stages (e.g., the recurrence rate among the first A patients was x percent, whereas the recurrence rate among the subsequent C patients was y percent). Other studies reported data comparing surgeons or centers with different levels of prior experience. All extracted information from the studies for this Key Question appear in Table 67 through Table 74 of Appendix C.

Table 14 Overview of Key Question 7 studies

Procedure | Total Number of Studies | Number That Compared Stages | Number That Compared Surgeons or Centers
TEP | 17 | 15 | 4
TAPP | 13 | 12 | 4
Combined TAPP/TEP | 3 | 0 | 3

Note: Two TEP studies and three TAPP studies reported data in two ways (compared stages and also compared surgeons/centers). Also, one study reported separate data on TEP and TAPP.

TAPP = Transabdominal preperitoneal repair; TEP = totally extraperitoneal repair.

Hernia recurrence (RC) rate is a time-sensitive outcome; therefore, studies should factor out the length of followup when measuring the association between surgical experience and RC. The problem is that those undergoing earlier operations have had more time to experience recurrence, and so an observed higher rate of recurrence may be caused simply by a time confound. Unfortunately, a full 26 of the 32 included studies (81 percent) failed to report data that factored out the length of followup. Some of these 26 studies acknowledged the time confound; however, these still did not report data in a more interpretable way (e.g., comparing 1-year recurrence rates between the first half of the series and the last half of the series).

Another problem with interpreting surgical experience data involves the evolution of surgical techniques over time. If a surgeon changes the mesh over time, or the details of the procedure for inserting the mesh, a reduction in recurrence rates may be due not to surgical expertise but rather procedural differences. Thirteen of the 32 included studies (41 percent) reported changing important procedural aspects over time, such as the size of the mesh (which typically involved the use of larger meshes in later time periods).

Another concern involves selective outcome reporting. Not all studies of laparoscopic hernioplasty have reported data on the association between surgical experience and RC. Of the 47 studies included for other laparoscopy Key Questions (Key Question 2 and/or Key Question 4), only 4 of 47 were included for this question, Key Question 7. The other 43 studies were focused on treatment comparisons rather than surgical experience; most of the 32 included studies for Key Question 7 were case series of laparoscopy.

This question focuses on surgical experience specific to laparoscopic hernia repair. Wright and colleagues (1998)82 asserted that general laparoscopic experience (i.e., experience with nonhernia laparoscopic procedures) does not necessary apply to laparoscopic hernia repair:82 “In addition, the fact that a surgeon has ample experience in one particular area of laparoscopic surgery does not mean that he or she will be able to operate in other areas without appropriate training. As pointed out by Grundfest, a surgeon who has performed 250 laparoscopic cholecystectomies will not be qualified to perform a laparoscopic colon resection. Additional training is required for any particular procedure before the surgeon incorporates it into his or her practice.”82

### Risk of Bias

We did not formally assess risk of bias for this Key Question because the question's intent is not to attribute cause. Above, we discussed our concerns about interpretation of the reported results on the association between surgical experience and RC.

### Findings

Unfortunately, the included studies reported data in markedly different ways (Table 15). Among studies comparing an early set to later set(s) of repairs, the size of the early set varied from a low of 10 repairs to a high of 825 repairs. The compared portions of the series were typically of different sizes. Granted, this can be addressed by using recurrence rates, but nevertheless it is unclear how authors chose their cut points; one possibility is that they structured their data with an eye toward showing the largest possible reduction in recurrence rates over time. The reporting differences mean that one cannot use the data to estimate the length of the learning curve for TEP or TAPP in the context of hernia repair. Interpretation is further compounded by common problems (mentioned above) of ignoring the time confound, procedural evolutions over time, and selective outcome reporting.

Table 15 Variation in reporting of Key Question 7 data

Study | How the Stages Were Reported
Bittner et al. 2002^204-208^ | First 600 hernia repairs vs. last 7,450 hernia repairs First 500 vs. next 1,700 vs. next 500 First 600 vs. next 4,405 First 132 vs. next 132
Bobrzynski et al. 2001^209^ | First 10 vs. last 326
Cheah et al. 2004^210^ | First 119 vs. last 63
Davies et al. 1995^211,212^ | First 10 vs. next 90 vs. next 100 vs. last 100
Dulucq et al. 2009^213^ | First 200 vs. next 1,254 vs. last 902
Edwards et al. 2000^214^ | First 30 vs. last 30 First 30 vs. last 27 First 30 vs. last 22
Feliu-Pala et al. 2001^215^ | First 100 vs. next 400 vs. last 491
Ferzli et al. 1995^216^ | First 100 vs. last 149
Geis et al. 1993^217^ | First 50 vs. last 314
Kapiris et al., 2001^218^ | First 325 vs. last 3,205
Kieturakis et al. 1994^219^ | First 20 vs. last 130
Lal et al. 2004^220^ | First 10 vs. next 10 vs. next 10 vs. last 26
Lau et al. 2002^221^ | First 20 vs. next 20 vs. next 20 vs. next 20 vs. next 20 vs. last 20
Liem et al. 1997^82,222-227^ | First 10 vs. next 10 vs. last 10
MRC et al. 1999^17,37,76-82^ | First 10 vs. next 10 vs. last 10
Pikoulis et al. 2002^228^ | First 50 vs. next 50 vs. last 209
Ramshaw et al. 2001^229^ | First 300 vs. last 624
Schultz et al. 2001^230^ | First 500 vs. next 500 vs. next 500 vs. next 500 vs. last 500
Swadia 2011^231^ | First 412 vs. next 535 vs. last 592
Tamme et al. 2003^232^ | First 825 vs. last 4,378
Voitk et al. 1998^233^ | First 50 vs. last 50
Zendejas et al. 2011^234^ | First 40 vs. next 40 vs. next 40 vs. next 40 vs. next 40 vs. next 40 vs. last 24 First 110 vs. last 866

Given this large variation, no meta-analysis was conducted. Instead, we present a general summary of the results in Table 16 below. Most studies reported results in the expected direction: lower recurrence rates with increased experience. This was also true when examined more specifically for TEP (11 of 17 studies) and TAPP (11 of 13 studies).

Table 16 Summary of results of Key Question 7 studies

Procedure | Lower Recurrence With Increased Experience | Mixed Results, No Effect, or No Recurrences Observed | Higher Recurrence With Increased Experience
TEP | 11 | 6 | 0
TAPP | 11 | 3 | 0
Combined TAPP/TEP | 1 | 1 | 1

TAPP = Transabdominal preperitoneal repair; TEP = totally extraperitoneal repair.

One study reported separate data on TEP and TAPP, so it is represented twice in the table (specifically in the column labeled “lower recurrence with increased experience”).

### Applicability

Thirty-two studies are included for review for Key Question 7. We evaluated these studies to identify factors that might affect the applicability of the evidence. As described in the Methods section, the goal of the evaluation is to raise stakeholders' attention to potential applicability issues embedded in the evidence rather than generating a rating or score for the applicability.

The 32 studies reviewed for Key Question 7 compared the recurrence rates of TAPP, TAP, or combined TAPP and TEP between surgeons or medical centers with varying experience or between surgeries operated earlier versus later in the series. Table 71 of Appendix C provides a detailed description of the laparoscopic procedures being studied. For Key Question 7, we summarized the findings separately by different procedures (Table 16) because the evidence for one type of laparoscopic procedure may not apply to a different type of procedure.

Except for three studies,231,234,235 the surgeries were all performed in 1990s or early 2000s. The findings about the experience-recurrence association may not necessarily apply to current state-of-the-art procedures.

Patient enrollment criteria and reported baseline characteristics varied significantly across the 32 studies. It is unclear whether any of the reported patient characteristics or enrollment criteria have a significant implication in the applicability of the overall evidence. Detailed patient enrollment criteria and baseline characteristics of these studies are provided in Table 68 and Table 72 of Appendix C.

Except for 8 studies36,83-88,214,216,217,219,229,234,236 all other 24 studies were performed outside of the United States, primarily in European countries. The differences in health care systems and practice patterns between the United States and other geographic regions might have an impact on the applicability of the evidence from the perspectives of U.S. stakeholders. The clinical setting varied significantly across the studies, ranging from community hospitals, to teaching or university hospitals, to specialized hernia or laparoscopy centers. The reported data do not allow us to judge whether the geographic or clinical settings have any significant impact on the applicability of the overall evidence. Based on the data reported, it is unclear how the clinical settings of the studies might have affected the applicability of the evidence. Detailed information on geographic and clinical settings of the six studies is provided in Table 67 of Appendix C.

### Summary of Key Question 7

This section found a large amount of evidence reporting that greater surgical experience with laparoscopic herniorrhaphy is associated with lower recurrence rates. The variations in reporting, however, made it impossible to estimate the length of the learning curve. Key problems arose in interpreting the data in three areas: the possibility of a time confound (that earlier patients had been followed for longer and had more time to have recurrences), procedural evolutions (that details of the procedure often changed over time making it difficult to pinpoint the effect of expertise), and selective outcome reporting (that the studies reporting this association may have chosen to do so because of the nature of the data).

We examined the abstracts of studies excluded for being non-English and found that 17 of them might have met all the other inclusion criteria for this Key Question.237-253 Thirteen involved TAPP, two involved TEP, one combined TAPP/TEP data, and one did not report which laparoscopic procedure had been performed. These studies were substantially similar to the 32 already included, with similar reports of decreasing recurrence over time, as well as the same problems in interpretation (e.g., no control for the time confound). Thus, their inclusion would not have altered our discussion of the evidence for this Key Question.

## Key Question 8 Pediatric patients: For a possible contralateral hernia, does same-operation repair/exploration differ from watchful waiting in patient-oriented effectiveness outcomes and/or adverse events?

No studies met the inclusion criteria for this question. The Discussion section contains a detailed discussion of this topic.

## Key Question 9 Pediatric patients: Does open hernia repair without a mesh differ from laparoscopic hernia repair without a mesh in patient-oriented effectiveness outcomes and/or adverse events?

### Study Characteristics

General information about the two studies included for this Key Question appears in Table 75 of Appendix C. One study was conducted in China, and the other one was conducted in Finland. Both studies were single-center RCTs conducted at a university hospital with an enrollment of 89 patients and 83 patients, respectively. The length of the enrollment period was 5.3 years for one study and 1 year for the second study. The second study's authors indicated that they had no financial relationship for disclosure.

Patient enrollment criteria appear in Table 76 (hernia-related criteria), Table 77 (demographic and medical criteria), and Table 78 (other criteria) of Appendix C. Enrollment criteria varied between the studies. Hernia-related study exclusion criteria included recurrent hernia (1 study), bilateral hernia (1 study), incarcerated hernia (both studies), femoral hernia (both studies), and “emergency” hernia (both studies). Regarding patient age criteria, one study enrolled patients aged 4 months to16 years, the other study enrolled patients aged older than 3 months to 9 years. As with the hernia-related exclusions, there was variability in how studies selected patients for inclusion.

Treatment details appear in Table 79 of Appendix C. Neither of the studies reported the actual number of prior laparoscopic hernia high ligations the surgeons had performed. One study did not mention surgeons' prior experience; the other one mentioned that the surgeon had general laparoscopy skills. Both studies reported baseline patient characteristics included for this Key Question (Table 80 of Appendix C). Most of the patients in the two studies were males.

### Risk of Bias

Our risk-of-bias assessments for both studies appear in Table 81 of Appendix C. Both RCTs were categorized as Moderate risk of bias for all of their reported outcomes. Common reasons for assigning a Moderate category to the studies were similar to those discussed in Key Question 2a: possible differences in prior surgical expertise, lack of concealment of allocation, and lack of outcome assessor blinding.

### Findings

All included data for this Key Question appear in Table 82 of Appendix C.

#### Hernia Recurrence

We performed a meta-analysis of both studies reporting this outcome (Figure 58) and found that the evidence was inconclusive (summary RR 1.54, 95% CI, 0.2 to 11.6).

Figure 58 Key Question 9: Meta-analysis of recurrence

(I^2^=0%, tau=0)

The figure shows the results of a meta-analysis comparing laparoscopic repair and open repair on the outcome Recurrence in the context of hernia in pediatrics. Points to the left of the midline favor laparoscopic repair, whereas points to the right of the midline favor open repair. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

#### Length of Hospital Stay

Both studies reported an outcome in length of hospital stay and were included in a meta-analysis (Figure 59). The meta-analysis found that length of stay was shorter after laparoscopic surgery than after open surgery (summary difference -1.13 hours, 95% CI, -1.77 to -0.49). Given the CI included values of less than 1 (what we defined as the MCSD) as well as values above 1, the finding's clinical significance remains unclear.

Figure 59 Key Question 9: Meta-analysis of length of stay

(I^2^=0%, tau=0)

The figure shows the results of a meta-analysis comparing laparoscopic repair and open repair on the outcome Length of Stay in the context of hernia in pediatrics. Points to the left of the midline favor laparoscopic repair, whereas points to the right of the midline favor open repair. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

#### Return to Daily Activities

Both studies reported an outcome in this category and were included in a meta-analysis of number of hours before returning to normal daily activities (Figure 60). The result of the meta-analysis was equivalent (summary difference -2.77 hours, 95% CI, -11.24 to 5.69).

Figure 60 Key Question 9: Meta-analysis of return to daily activities

(I^2^=58%, tau=26)

The figure shows the results of a meta-analysis comparing laparoscopic repair and open repair on the outcome Return to Activities of Daily Living in the context of hernia in pediatrics. Points to the left of the midline favor laparoscopic repair, whereas points to the right of the midline favor open repair. Each square is a single study, with its 95% confidence interval represented by the horizontal segments to the left and right of the point. The size of each point indicates the inverse standard error of the study, with larger points indicating smaller standard errors. The diamond is the summary effect size, with its confidence interval, and is shown at the bottom.

#### Long-Term Patient Satisfaction

One study reported long-term SFN. Patient SFN was recorded (unsatisfactory = 0, satisfactory = 1, good = 2, and excellent = 3) by patients or parents, the attending nurse, and the surgeon (minimum points = 0, maximum points = 9). The parents were more satisfied (difference in SFN points 1, 95% CI, 0.47 to 1.53) in the laparoscopic group compared with the open group.

#### Long-Term Cosmesis

One study reported this outcome. Cosmesis was recorded (unsatisfactory = 0, satisfactory = 1, good = 2, and excellent = 3) by patients or parents, the attending nurse, and the surgeon (minimum points = 0, maximum points = 9). The parents in the laparoscopic group were more content with cosmesis than those in the open group (difference in SFN points 0.25; 95% CI, 0.12 to 0.38).

### Applicability

Two studies are included for review for Key Question 9. We evaluated these studies to identify factors that might affect the applicability of the evidence. As described in the Methods section, the goal of the evaluation is to draw stakeholders' attention to potential applicability issues embedded in the evidence rather than generating a rating or score for the applicability.

Both studies compared open with laparoscopic procedures. The procedures in the Chan study were performed from 2003 to 2004,^254^ and those in the Koivusalo study were performed from 2002 to 2007.^255^ The evidence may not reflect the comparative effectiveness and safety of the current state-of-the-art open versus laparoscopic procedures. Surgeons' prior experiences for the procedures being compared were not reported in the studies. We were unable to judge whether there is any applicability issues related to surgeons' prior experiences.

Neither study included very young patients. The Chan study excluded patients younger than 3 months, and the Koivusalo study excluded patients younger than 4 months. Meanwhile, both studies excluded patients with incarcerated or strangulated hernia. The findings of the studies may not apply to the patient populations being excluded. Both studies also used additional patient exclusion criteria. For example, the Chan study did not include patients with recurrent hernia, and the Koivusalo study did not include patients with bilateral hernia. Other patient enrollment criteria used by the two studies are provided in Table 76, Table 77 and Table 78 of Appendix C. The findings of the studies may have a more restricted applicability in the populations being excluded from the studies.

Both studies were conducted outside of the United States; the Chan study was conducted in Hong Kong, and the Koivusalo study was conducted in Finland. The differences in health care systems and practice patterns between the United States and other regions might have an impact on the applicability of the evidence from the perspectives of U.S. stakeholders. Both studies were conducted in a university hospital. The evidence is potentially more applicable to academic settings.

### Summary of Key Question 9

A summary of the comparisons and outcomes we examined in this Key Question is in Table 17 below. Of the five outcomes reported, the evidence was sufficient to permit a conclusion for three outcomes:

- Three outcomes favored laparoscopy (length of stay, long-term SFN, and long-term cosmesis)
- One outcome indicated approximate equivalence comparing laparoscopy with open high ligation (return to daily activities)

Table 17 Key Question 9: Strength of evidence ratings

Comparison | Outcome | # Studies | Overall Risk of Bias | Consistency | Directness | Precision | Evidence Favors | SOE Rating
Laparoscopic vs. open high ligation | Length of stay (hours) | 2 | MOD | C | D | P Diff in means -1.13 (-1.77 to -0.49) | Laparoscopic | MOD
Laparoscopic vs. open high ligation | Return to daily activities (hours) | 2 | MOD | I | D | P Diff in means -2.77 (-11.24 to 5.69) | EQ | LOW
Laparoscopic vs. open high ligation | Recurrence | 2 | MOD | I | D | I RR 1.54 (0.2 to 11.6) | ? | INSUFF
Laparoscopic vs. open high ligation | Long-term patient satisfaction | 1 | MOD | U | D | P Diff in means 1.00 (0.47 to 1.53) | Laparoscopic | LOW
Laparoscopic vs. open high ligation | Long-term cosmesis | 1 | MOD | U | D | P Diff in means 0.25 (0.12 to 0.38) | Laparoscopic | LOW

Diff = difference

For consistency, C = consistent, I = inconsistent, U = unknown consistency because there was only one study.

For directness, D = direct, I = indirect.

For precision, I = imprecise, P = precise.

For the column labeled “Evidence favors,” ? denotes inconclusive evidence, and EQ denotes approximate equivalence.

For the column labeled SOE rating, SOE = strength of evidence, INSUFF = insufficient,

* indicates that the SOE was upgraded due to a large magnitude of effect. and

† indicates that the SOE was downgraded due to publication bias or selective outcome reporting.

Our ratings of the SOE for these outcomes also appear in Table 17. Studies were all at Moderate risk of bias (see the pertinent section above); some inconsistencies were found for some outcomes based on effect sizes on opposite sides of a null effect; all of these outcomes are directly important to clinicians and patients; imprecision was found for some outcomes that precluded conclusions. Questions about the relative importance of these outcomes need to be considered carefully. We examined the studies that had been excluded for being non-English language publications, none of which would have been included for this Key Question.