# References

1 Nicks BA, Askew K. Hernias. eMedicine. [database online]. Omaha (NE). eMedicine.com. 2010. Jan. 25. 2010 Jul 14. Available: http://emedicine.medscape.com/article/775630-overview.
2 Inguinal hernia: epidemiology. [database online]. San Mateo (CA). Epocrates, Inc. 2010. 2010 Jul 14. [1 p]. Available: https://online.epocrates.com/noFrame/showPage.do?method=diseases&MonographId=723&ActiveSectionId=23.
3 Schneider E. Inguinal hernia: excerpt from The 5-minute pediatric consult. [internet]. Health Grades Inc. 2008. 2011 Jan 26. [6 p]. Available: http://www.wrongdiagnosis.com/i/inguinal_hernia/book-diseases-20a.htm.
4 Brandt ML. Pediatric hernias. Surg Clin North Am. Feb. 2008;88(1):27-43. vii. viii. [pmid: 18267160].
5 Rutkow IM. Demographic and socioeconomic aspects of hernia repair in the United States in 2003. Surg Clin North Am. Oct. 2003;83(5):1045-51. v. vi. [pmid: 14533902].
6 Farley D. (Mayo Clinic, Rochester, MN). Personal communication. 2011. Dec. 1.
7 Zhao G, Gao P, Ma B, et al. Open mesh techniques for inguinal hernia repair: a meta-analysis of randomized controlled trials. Ann Surg. Jul. 2009;250(1):35-42. [pmid: 19561484].
8 Sherwinter DA, Lavotshkin S. Hernia inguinal repair, open: treatment & medication. [internet]. eMedicine. [updated 2009 Jul 24]. 2011 Jan 26. [23 p]. Available: http://emedicine.medscape.com/article/1534281-treatment.
9 Jacobs DO. Mesh repair of inguinal hernias--redux. N Engl J Med. Apr. 29. 2004;350(18):1895-7. [pmid: 15107484].
10 Owens DK, Lohr KN, Atkins D, et al. Grading the strength of a body of evidence when comparing medical interventions-Agency for Healthcare Research and Qualityn and the Effective Health Care Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
11 Simons MP, Aufenacker T, Bay-Nielson M, et al. European Hernia Society guidelines on the treatment of inguinal hernia in adult patients. Hernia. 2009;13:343-403. [pmid: 19636493].
12 Fitzgibbons RJ Jr, Giobbie-Hurder A, Gibbs JO, et al. Watchful waiting vs repair of inguinal hernia in minimally symptomatic men: a randomized clinical trial. JAMA. Jan. 18. 2006;295(3):285-92. [pmid: 16418463].
13 Hebra A. Pediatric hernias. [internet]. eMedicine. [updated 2010 Feb 25]. 2011 Jan 26. [23 p]. Available: http://emedicine.medscape.com/article/932680-overview.
14 Zollinger RM Jr. Classification systems for groin hernias. Surg Clin North Am. Oct. 2003;83(5):1053-63. [pmid: 14533903].
15 Nyhus LM. Individualization of hernia repair: a new era. Surgery. Jul. 1993;114(1):1-2. [pmid: 8356511].
16 Stoppa R. Hernias of the abdominal wall. Chevrel JP, editor. Hernias and surgery of the abdominal wall. Berlin. Springer. 1998:171-277.
17 Kumar S, Nixon SJ, MacIntyre IM. Laparoscopic or Lichtenstein repair for recurrent inguinal hernia: one unit's experience. J R Coll Surg Edinb. Oct. 1999;44(5):301-2. [pmid: 10550952].
18 Sanders DL, Samarakoon DH, Ganshirt SW, et al. A two-centre blinded randomised control study comparing the Lichtenstein patch, Perfix plug and ProLoop plug in the repair of primary inguinal hernia. Hernia. Oct. 2009;13(5):499-503. [pmid: 19644646].
19 Dalenback J, Andersson C, Anesten B, et al. Prolene Hernia System, Lichtenstein mesh and plug-and-patch for primary inguinal hernia repair: 3-year outcome of a prospective randomised controlled trial. The BOOP study: [TRUNC]. Hernia. Apr. 2009;13(2):121-9. discussion 231. [pmid: 19015933].
20 Abu-Own A, Onwudike M, Haque KA, et al. Primary inguinal hernia repair utilizing the mesh ‘plug’ technique. Ambul Surg. Jan. 2000;8(1):31-5.
21 Wake BL, McCormack K, Fraser C, et al. Transabdominal pre-peritoneal (TAPP) vs totally extraperitoneal (TEP) laparoscopic techniques for inguinal hernia repair. Cochrane Database of Systematic Reviews. [internet]. Hoboken (NJ). John Wiley & Sons, Ltd. 2005;(1). 2010 Jul 2. [Art. No.: CD004703]. Available:. [doi: 10.1002/14651858.CD004703.pub2]. [pmid: 15674961].
22 Jenkins JT, O'Dwyer PJ. Inguinal hernias. BMJ. Feb. 2. 2008;336(7638):269-72. [pmid: 18244999].
23 Eklund A, Rudberg C, Leijonmarck CE, et al. Recurrent inguinal hernia: randomized multicenter trial comparing laparoscopic and Lichtenstein repair. Surg Endosc. Apr. 2007;21(4):634-40. [pmid: 17364153].
24 Wara P, Bay-Nielsen M, Juul P, et al. Prospective nationwide analysis of laparoscopic versus Lichtenstein repair of inguinal hernia. Br J Surg. Oct. 2005;92(10):1277-81. [pmid: 16003727].
25 Kocijan R, Sandberg S, Chan YW, et al. Anatomical changes after inguinal hernia treatment: a reason for chronic pain and recurrent hernia. Surg Endosc. Feb. 2010;24(2):395-9. [pmid: 19551430].
26 Information on surgical mesh for hernia repairs. [internet]. Silver Spring (MD). Food and Drug Administration. [updated 2011 Jul 13]. 2011 Oct 27. [2 p]. Available: http://www.fda.gov/MedicalDevices/Safety/AlertsandNotices/ucm142636.htm#hernia.
27 Davol, C.R. Bard. Bard composix kugel mesh patch - expansion. Class 1 recall. [internet]. Silver Spring (MD). Food and Drug Administration. 2005. Dec. 22. [updated 2010 Jun 30]. 2011 Oct 27. [2 p]. Available: http://www.fda.gov/MedicalDevices/Safety/RecallsCorrectionsRemovals/ListofRecalls/ucm062944.htm.
28 Davol, C.R. Bard. Davol Inc., xenmatrix surgical graft. Class 1 recall. [internet]. Silver Spring (MD). Food and Drug Administration. 2011. Jan. 11. [updated 2011 Mar 7]. 2011 Oct 27. [1 p]. Available: http://www.fda.gov/MedicalDevices/Safety/RecallsCorrectionsRemovals/ListofRecalls/ucm245714.htm.
29 Counterfeit polypropylene surgical mesh products marketed as C. R. Bard/Davol. [internet]. Silver Spring (MD). Food and Drug Administration. 2010. Mar. 5. [updated 2010 Jun 30]. 2011 Oct 27. [2 p]. Available: http://www.fda.gov/MedicalDevices/Safety/RecallsCorrectionsRemovals/ListofRecalls/ucm214821.htm.
30 Sanabria A, Dominguez LC, Valdivieso E, et al. Prophylactic antibiotics for mesh inguinal hernioplasty: a meta-analysis. Ann Surg. Mar. 2007;245(3):392-6. [pmid: 17435546].
31 Nienhuijs S, Staal E, Strobbe L, et al. Chronic pain after mesh repair of inguinal hernia: a systematic review. Am J Surg. Sep. 2007;194(3):394-400. [pmid: 17693290].
32 Narine L, Yee DS, Einarson TR, et al. Quality of abstracts of original research articles in CMAJ in 1989. CMAJ. Feb. 15. 1991;144(4):449-53. [pmid: 1993292].
33 Pitkin RM, Branagan MA, Burmeister LF. Accuracy of data in abstracts of published research articles. JAMA. Mar. 24-31. 1999;281(12):1110-1. [pmid: 10188662].
34 Moher D, Pham B, Klassen TP, et al. What contributions do languages other than English make on the results of meta-analyses?. J Clin Epidemiol. Sep. 2000;53(9):964-72. [pmid: 11004423].
35 Juni P, Holenstein F, Sterne J, et al. Direction and impact of language bias in meta-analyses of controlled trials: empirical study. Int J Epidemiol. Feb. 2002;31(1):115-23. [pmid: 11914306].
36 Neumayer L, Giobbie-Hurder A, Jonasson O, et al. Open mesh versus laparoscopic mesh repair of inguinal hernia. N Engl J Med. Apr. 29. 2004;350(18):1819-27. [pmid: 15107485].
37 Laparoscopic versus open repair of groin hernia: a randomised comparison. The MRC Laparoscopic Groin Hernia Trial Group. Lancet. Jul. 17. 1999;354(9174):185-90. [pmid: 10421299].
38 Hagg O, Fritzell P, Nordwall A, et al. The clinical importance of changes in outcome scores after treatment for chronic low back pain. Eur Spine J. Feb. 2003;12(1):12-20. [pmid: 12592542].
39 Guidance for industry: statistical approaches to establishing bioequivalence. Rockville (MD). U.S. Department of Health and Human Services, Food and Drug Administration, Center for Drug Evaluation and Research. Jan. 2001:48. Also available: http://www.fda.gov/downloads/Drugs/GuidanceComplianceRegulatoryInformation/Guidances/ucm070244.pdf.
40 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. Sep. 1986;7(3):177-88. [pmid: 3802833].
41 Rucker G, Schwarzer G, Carpenter JR, et al. Undue reliance on I^2 in assessing heterogeneity may mislead. BMC Med Res Methodol. Nov. 27. 2008;8(1):79. [pmid: 19036172].
42 Higgins JP, Thompson SG. Controlling the risk of spurious findings from meta-regression. Stat Med. Jun. 15. 2004;23(11):1663-82. [pmid: 15160401].
43 Atkins D, Chang S, Gartlehner G, et al. Assessing applicability when comparing medical interventions: Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. 2011. Apr. 2. [pmid: 21463926].
44 Stroupe KT, Manheim LM, Luo P, et al. Tension-free repair versus watchful waiting for men with asymptomatic or minimally symptomatic inguinal hernias: a cost-effectiveness analysis. J Am Coll Surg. Oct. 2006;203(4):458-68. [pmid: 17000388].
45 O'Dwyer PJ, Chung L. Watchful waiting was as safe as surgical repair for minimally symptomatic inguinal hernias: commentary. Evid Based Med. Jun. 2006;11(3):73. [pmid: 17213095].
46 Watchful waiting acceptable option for inguinal hernia. J Fam Pract. Apr. 2006;55(4):282.
47 Gibbs JO, Giobbie-Hurder A, Edelman P, et al. Does delay of hernia repair in minimally symptomatic men burden the patient's family?. J Am Coll Surg. Sep. 2007;205(3):409-12. [pmid: 17765156].
48 Fitzgibbons RJ, Jonasson O, Gibbs J, et al. The development of a clinical trial to determine if watchful waiting is an acceptable alternative to routine herniorrhaphy for patients with minimal or no hernia symptoms. J Am Coll Surg. May. 2003;196(5):737-42. [pmid: 12742207].
49 Sarosi GA, Wei Y, Gibbs JO, et al. A Clinician's guide to patient selection for watchful waiting management of inguinal hernia. Ann Surg. Mar. 2011;253(3):605-10. [pmid: 21239979].
50 O'Dwyer PJ, Norrie J, Alani A, et al. Observation or operation for patients with an asymptomatic inguinal hernia: a randomized clinical trial. Ann Surg. Aug. 2006;244(2):167-73. [pmid: 16858177].
51 Chung L, Norrie J, O'Dwyer PJ. Long-term follow-up of patients with a painless inguinal hernia from a randomized clinical trial. Br J Surg. Apr. 2011;98(4):596-9. [pmid: 21656724].
52 Amid PK, Shulman AG, Lichtenstein IL. The Lichtenstein open ‘tension-free’ mesh repair of inguinal hernias. Surg Today. 1995;25(7):619-25. [pmid: 7549274].
53 Anadol ZA, Ersoy E, Taneri F, et al. Outcome and cost comparison of laparoscopic transabdominal preperitoneal hernia repair versus Open Lichtenstein technique. J Laparoendosc Adv Surg Tech A. Jun. 2004;14(3):159-63. [pmid: 15245668].
54 Andersson B, Hallen M, Leveau P, et al. Laparoscopic extraperitoneal inguinal hernia repair versus open mesh repair: a prospective randomized controlled trial. Surgery. May. 2003;133(5):464-72. [pmid: 12773973].
55 Hallen M, Bergenfelz A, Westerdahl J. Laparoscopic extraperitoneal inguinal hernia repair versus open mesh repair: long-term follow-up of a randomized controlled trial. Surgery. Mar. 2008;143(3):313-7. [pmid: 18291251].
56 Bringman S, Ramel S, Heikkinen TJ, et al. Tension-free inguinal hernia repair: TEP versus mesh-plug versus Lichtenstein: a prospective randomized controlled trial. Ann Surg. Jan. 2003;237(1):142-7. [pmid: 12496542].
57 Butler RE, Burke R, Schneider JJ, et al. The economic impact of laparoscopic inguinal hernia repair: results of a double-blinded, prospective, randomized trial. Surg Endosc. Mar. 2007;21(3):387-90. [pmid: 17235721].
58 Champault GG, Rizk N, Catheline JM, et al. Inguinal hernia repair: totally preperitoneal laparoscopic approach versus Stoppa operation: randomized trial of 100 cases. Surg Laparosc Endosc. Dec. 1997;7(6):445-50. [pmid: 9438623].
59 Occelli G, Barrat C, Catheline JM, et al. Laparoscopic treatment of inguinal hernias: prospective evaluation of 757 cases treated by a totally extraperitoneal route. Hernia. Jun. 2000;4(2):81-4.
60 Champault G, Rizk N, Catheline JM, et al. Inguinal hernia. Pre-peritoneal laparoscopic surgery vs. the Stoppa procedure. A prospective randomized trial: 100 cases. J Chir (Paris). Sep. 1996;133(6):274-80. [pmid: 8949271].
61 Hernies de l'aine. Resultats a 4 ans deux etudes prospectives randomisees comparant les operations de Shouldice et de Stoppa a l'abord laparoscopique totalement pre-peritoneal (461 patients). Ann Chir. 1998;52:132-6. [pmid: 9752429].
62 Eklund A, Rudberg C, Smedberg S, et al. Short-term results of a randomized clinical trial comparing Lichtenstein open repair with totally extraperitoneal laparoscopic inguinal hernia repair. Br J Surg. Sep. 2006;93(9):1060-8. [pmid: 16862612].
63 Eklund A, Carlsson P, Rosenblad A, et al. Long-term cost-minimization analysis comparing laparoscopic with open (Lichtenstein) inguinal hernia repair. Br J Surg. May. 2010;97(5):765-71. [pmid: 20186996].
64 Eklund A, Montgomery A, Bergkvist L, et al. Chronic pain 5 years after randomized comparison of laparoscopic and Lichtenstein inguinal hernia repair. Br J Surg. Apr. 2010;97(4):600-8. [pmid: 20186889].
65 Eklund AS, Montgomery AK, Rasmussen IC, et al. Low recurrence rate after laparoscopic (TEP) and open (Lichtenstein) inguinal hernia repair: a randomized, multicenter trial with 5-year follow-up. Ann Surg. Jan. 2009;249(1):33-8. [pmid: 19106673].
66 Gong K, Zhang N, Lu Y, et al. Comparison of the open tension-free mesh-plug, transabdominal preperitoneal (TAPP), and totally extraperitoneal (TEP) laparoscopic techniques for primary unilateral inguinal hernia repair: a prospective randomized controlled trial. Surg Endosc. Jan. 2011;25(1):234-9. [pmid: 20552368].
67 Gunal O, Ozer S, Gurleyik E, et al. Does the approach to the groin make a difference in hernia repair?. Hernia. Oct. 2007;11(5):429-34. [pmid: 17610024].
68 Heikkinen TJ, Haukipuro K, Hulkko A. A cost and outcome comparison between laparoscopic and Lichtenstein hernia operations in a day-case unit. A randomized prospective study. Surg Endosc. Oct. 1998;12(10):1199-203. [pmid: 9745056].
69 Heikkinen T, Bringman S, Ohtonen P, et al. Five-year outcome of laparoscopic and Lichtenstein hernioplasties. Surg Endosc. Mar. 2004;18(3):518-22. [pmid: 14735339].
70 Johansson B, Hallerback B, Glise H, et al. Laparoscopic mesh versus open preperitoneal mesh versus conventional technique for inguinal hernia repair: a randomized multicenter trial (SCUR Hernia Repair Study). Ann Surg. Aug. 1999;230(2):225-31. [pmid: 10450737].
71 Johansson B, Hallerback B, Gilse H, et al. Laparscopic mesh repair vs open repair w/wo mesh graft for inguinal hernia (SCUR groin hernia repair study). Preliminary results. [abstract S03]. Surg Endosc. 1997;11:170.
72 Koninger J, Redecke J, Butters M. Chronic pain after hernia repair: a randomized trial comparing Shouldice, Lichtenstein and TAPP. Langenbecks Arch Surg. Oct. 2004;389(5):361-5. [pmid: 15243743].
73 Lal P, Kajla RK, Chander J, et al. Randomized controlled study of laparoscopic total extraperitoneal versus open Lichtenstein inguinal hernia repair. Surg Endosc. Jun. 2003;17(6):850-6. [pmid: 12658428].
74 Langeveld HR, van't Riet M, Weidema WF, et al. Total extraperitoneal inguinal hernia repair compared with Lichtenstein (the LEVEL-Trial): a randomized controlled trial. Ann Surg. May. 2010;251(5):819-24. [pmid: 20395851].
75 Lau H, Patil NG, Yuen WK. Day-case endoscopic totally extraperitoneal inguinal hernioplasty versus open Lichtenstein hernioplasty for unilateral primary inguinal hernia in males: a randomized trial. Surg Endosc. Jan. 2006;20(1):76-81. [pmid: 16247575].
76 Wright D, Paterson C, Scott N, et al. Five-year follow-up of patients undergoing laparoscopic or open groin hernia repair: a randomized controlled trial. Ann Surg. Mar. 2002;235(3):333-7. [pmid: 11882754].
77 Medical Research Council Laparoscopic Groin Hernia Trial Group. Cost-utility analysis of open versus laparoscopic groin hernia repair: results from a multicentre randomized clinical trial. Br J Surg. May. 2001;88(5):653-61. [pmid: 11350435].
78 Wright DM, Hall MG, Paterson CR, et al. A randomized comparison of driver reaction time after open and endoscopic tension-free inguinal hernia repair. Surg Endosc. Apr. 1999;13(4):332-4. [pmid: 10094741].
79 Wright DM, Kennedy A, Baxter JN, et al. Early outcome after open versus extraperitoneal endoscopic tension-free hernioplasty: a randomized clinical trial. Surgery. May. 1996;119(5):552-7. [pmid: 8619212].
80 Scott NW, Grant AM, Ross SJ, et al. Patient-assessed outcome up to three months in a randomized controlled trial comparing laparoscopic with open groin hernia repair. Hernia. 2000;4:73-9.
81 Grant AM, Scott NW, O'Dwyer PJ, et al. Five-year follow-up of a randomized trial to assess pain and numbness after laparoscopic or open repair of groin hernia. Br J Surg. Dec. 2004;91(12):1570-4. [pmid: 15515112].
82 Wright D, O'Dwyer PJ. The learning curve for laparoscopic hernia repair. Semin Laparosc Surg. Dec. 1998;5(4):227-32. [pmid: 9854130].
83 Hynes DM, Stroupe KT, Luo P, et al. Cost effectiveness of laparoscopic versus open mesh hernia operation: results of a Department of Veterans Affairs randomized clinical trial. J Am Coll Surg. Oct. 2006;203(4):447-57. [pmid: 17000387].
84 Matthews RD, Anthony T, Kim LT, et al. Factors associated with postoperative complications and hernia recurrence for patients undergoing inguinal hernia repair: a report from the VA Cooperative Hernia Study Group. Am J Surg. Nov. 2007;194(5):611-7. [pmid: 17936422].
85 Kaafarani HM, Itani KM, Giobbie-Hurder A, et al. Does surgeon frustration and satisfaction with the operation predict outcomes of open or laparoscopic inguinal hernia repair?. J Am Coll Surg. May. 2005;200(5):677-83. [pmid: 15848357].
86 Neumayer L, Jonasson O, Fitzgibbons R, et al. Tension-free inguinal hernia repair: the design of a trial to compare open and laparoscopic surgical techniques. J Am Coll Surg. May. 2003;196(5):743-52. [pmid: 12742208].
87 Neumayer LA, Gawande AA, Wang J, et al. Proficiency of surgeons in inguinal hernia repair: effect of experience and age. Ann Surg. Sep. 2005;242(3):344-8. discussion 348-52. [pmid: 16135920].
88 Wilkiemeyer M, Pappas TN, Giobbie-Hurder A, et al. Does resident post graduate year influence the outcomes of inguinal hernia repair?. Ann Surg. Jun. 2005;241(6):879-82. discussion 882-4. [pmid: 15912037].
89 Paganini AM, Lezoche E, Carle F, et al. A randomized, controlled, clinical study of laparoscopic vs open tension-free inguinal hernia repair. Surg Endosc. Jul. 1998;12(7):979-86. [pmid: 9632874].
90 Payne JH Jr, Grininger LM, Izawa MT, et al. Laparoscopic or open inguinal herniorrhaphy? A randomized prospective trial. Arch Surg. Sep. 1994;129(9):973-9. discussion 979-81. [pmid: 8080380].
91 Picchio M, Lombardi A, Zolovkins A, et al. Tension-free laparoscopic and open hernia repair: randomized controlled trial of early results. World J Surg. Oct. 1999;23(10):1004-7. discussion 1008-9. [pmid: 10512939].
92 Pokorny H, Klingler A, Schmid T, et al. Recurrence and complications after laparoscopic versus open inguinal hernia repair: results of a prospective randomized multicenter trial. Hernia. Aug. 2008;12(4):385-9. [pmid: 18283518].
93 Pokorny H, Klingler A, Scheyer M, et al. Postoperative pain and quality of life after laparoscopic and open inguinal hernia repair: results of a prospective randomized trial. Hernia. Aug. 2006;10(4):331-7. [pmid: 16819563].
94 Simmermacher RK, Van Duyn EB, Clevers GJ, et al. Preperitoneal mesh in groin hernia surgery: a randomized trial emphasizing the surgical aspects of perperitoneal placement via a laparoscopic (TEP) or Grid-iron (Ugahary) approach. Hernia. 2000;4:296-8.
95 Zieren J, Zieren HU, Jacobi CA, et al. Prospective randomized study comparing laparoscopic and open tension-free inguinal hernia repair with Shouldice's operation. Am J Surg. Apr. 1998;175(4):330-3. [pmid: 9568665].
96 Zieren J, Zieren HU, Said S, et al. Laparoscopic or conventional groin hernia repair with or without implant. A prospective randomized study. Langenbecks Arch Chir. Suppl II. 1996:609-10. [pmid: 9101947].
97 Hildebrandt J, Levantin O. Tension-free methods of surgery of primary inguinal hernias. Comparison of endoscopic, total extraperitoneal hernioplasty with the Lichtenstein operation. Chirurg. Oct. 2003;74(10):915-21. [pmid: 14605733].
98 Sarli L, Pietra N, Choua O, et al. Prospective randomized comparative study of laparoscopic hernioplasty and Lichtenstein tension-free hernioplasty. Acta Biomed Ateneo Parmense. 1997;68(1-2):5-10. [pmid: 9478251].
99 Onofrio L, Cafaro D, Manzo F, et al. Tension-free laparoscopic versus open inguinal hernia repair. Minerva Chir. Aug. 2004;59(4):369-77. [pmid: 15278032].
100 Catani M, De Milito R, Spaziani E, et al. Laparoscopic inguinal hernia repair “IPOM” vs “open tension free”. Preliminary results of a prospective randomized study. Minerva Chir. Dec. 2003;58(6):783-9. [pmid: 14663405].
101 Tavassoli A, Ghamari MJ, Esmaily H. Repair of inguinal hernia: a comparison between extraperitoneal laparoscopy and Lichtenstein open surgery. Tehran Univ Med J. Jun. 2010;68(3):168-74.
102 Kuthe A, Flade-Kuthe R, Schmitz R, et al. Total extraperitoneal endoscopic patch plasty (TEP) versus open tension-free repair of inguinal hernia. A prospective two-centre study for documentation of postoperative pain. Chir Prax. Dec. 2003;62(2):231-8.
103 Krska Z, Kvasnicka J, Peskova M, et al. The acute phase reaction in laparoscopic and open surgery of inguinal hernias. Rozhl Chir. May. 2001;80(5):253-6. [pmid: 11392049].
104 Gainant A, Geballa R, Bouvier S, et al. Prosthetic treatment of bilateral inguinal hernias via laparoscopic approach or Stoppa procedure. Ann Chir. Jul. 2000;125(6):560-5. [pmid: 10986768].
105 Angelescu N, Jitea N, Burcos T, et al. The classical or laparoscopic operation in inguinal hernias. Chirurgia (Bucur). Jul-Aug. 1998;93(4):213-6. [pmid: 9755570].
106 Champault G, Barrat C, Catheline JM, et al. Inguinal hernia. 4-year follow-up of 2 comparative prospective randomized studies of Shouldice and Stoppa operations with pre-peritoneal totally laparoscopic approach (461 patients). Ann Chir. 1998;52(2):132-6. [pmid: 9752429].
107 Ozmen M, Zulfikaroglu B, Ozalp N, et al. Femoral vessel blood flow dynamics following totally extraperitoneal vs Stoppa procedure in bilateral inguinal hernias. Am J Surg. Jun. 2010;199(6):741-5. [pmid: 20609719].
108 Bisgaard T, Bay-Nielsen M, Christensen IJ, et al. Risk of recurrence 5 years or more after primary Lichtenstein mesh and sutured inguinal hernia repair. Br J Surg. Aug. 2007;94(8):1038-40. [pmid: 17607708].
109 Bay-Nielsen M, Perkins FM, Kehlet H, et al. Pain and functional impairment 1 year after inguinal herniorrhaphy: a nationwide questionnaire study. Ann Surg. Jan. 2001;233(1):1-7. [pmid: 11141218].
110 Bay-Nielsen M, Kehlet H. Anaesthesia and post-operative morbidity after elective groin hernia repair: a nation-wide study. Acta Anaesthesiol Scand. Feb. 2008;52(2):169-74. [pmid: 17999709].
111 Bay-Nielsen M, Nilsson E, Nordin P, et al. Chronic pain after open mesh and sutured repair of indirect inguinal hernia in young males. Br J Surg. Oct. 2004;91(10):1372-6. [pmid: 15376186].
112 Bisgaard T, Bay-Nielsen M, Kehlet H. Re-recurrence after operation for recurrent inguinal hernia. A nationwide 8-year follow-up study on the role of type of repair. Ann Surg. Apr. 2008;247(4):707-11. [pmid: 18362636].
113 Beets GL, Dirksen CD, Go PM, et al. Open or laparoscopic preperitoneal mesh repair for recurrent inguinal hernia? A randomized controlled trial. Surg Endosc. Apr. 1999;13(4):323-7. [pmid: 10094739].
114 Frey DM, Wildisen A, Hamel CT, et al. Randomized clinical trial of Lichtenstein's operation versus mesh plug for inguinal hernia repair. Br J Surg. Jan. 2007;94(1):36-41. [pmid: 17094166].
115 Hamza Y, Gabr E, Hammadi H, et al. Four-arm randomized trial comparing laparoscopic and open hernia repairs. Int J Surg. 2010;8(1):25-8. [pmid: 19796714].
116 Muldoon RL, Marchant K, Johnson DD, et al. Lichtenstein vs anterior preperitoneal prosthetic mesh placement in open inguinal hernia repair: a prospective, randomized trial. Hernia. May. 2004;8(2):98-103. [pmid: 14625698].
117 Vatansev C, Belviranli M, Aksoy F, et al. The effects of different hernia repair methods on postoperative pain medication and CRP levels. Surg Laparosc Endosc Percutan Tech. Aug. 2002;12(4):243-6. [pmid: 12193818].
118 Sevonius D, Gunnarsson U, Nordin P, et al. Repeated groin hernia recurrences. Ann Surg. Mar. 2009;249(3):516-8. [pmid: 19247043].
119 Magnusson N, Nordin P, Hedberg M, et al. The time profile of groin hernia recurrences. Hernia. Aug. 2010;14(4):341-4. [pmid: 20340036].
120 Nordin P, Van Der Linden W. Volume of procedures and risk of recurrence after repair of groin hernia: national register study. BMJ. Apr. 26. 2008;336(7650):934-7. [pmid: 18426843].
121 Franneby U, Sandblom G, Nordin P, et al. Risk factors for long-term pain after hernia surgery. Ann Surg. Aug. 2006;244(2):212-9. [pmid: 16858183].
122 Nordin P, Haapaniemi S, Kald A, et al. Influence of suture material and surgical technique on risk of reoperation after non-mesh open hernia repair. Br J Surg. Aug. 1. 2003;90(8):1004-8. [pmid: 12905556].
123 Subwongcharoen S. Outcome of inguinal hernia repair total extraperitoneal laparoscopic hernia repair versus open tension free repair (Lichtenstein technique). J Med Assoc Thai. Oct. 2002;85(10):1100-3. [pmid: 12501902].
124 Haapaniemi S, Gunnarsson U, Nordin P, et al. Reoperation after recurrent groin hernia repair. Ann Surg. Jul. 2001;234(1):122-6. [pmid: 11420492].
125 Novik B, Nordin P, Skullman S, et al. More recurrences after hernia mesh fixation with short-term absorbable sutures: A registry study of 82 015 Lichtenstein repairs. Arch Surg. Jan. 2011;146(1):12-7. [pmid: 21242440].
126 Simanek V, Treska V, Spidlen V, et al. Open inguinal hernioplasty, comparison of various techniques--a pilot study. Rozhl Chir. Dec. 2005;84(12):595-8. [pmid: 16447578].
127 Zandi G, Vasquez G, Ortolani M, et al. Inguinal hernia prosthetic repair through the anterior approach. Minerva Chir. Oct. 2001;56(5):467-74. [pmid: 11568721].
128 Testini M, Miniello S, Piccinni G, et al. Trabucco versus Rutkow versus Lichtenstein techniques in the treatment of groin hernia. A controlled randomized clinical trial. Minerva Chir. Jun. 2002;57(3):371-6. [pmid: 12029233].
129 Li N, Song MM, Jia YL, et al. Comparative study of mesh-plug and polypropylene hernia system tension-free hernioplasty for inguinal hernia. Zhonghua Yi Xue Za Zhi. Jul. 1. 2008;88(25):1756-8. [pmid: 19035086].
130 Kendall C, Murray S. Is watchful waiting a reasonable approach for men with minimally symptomatic inguinal hernia?. CMAJ. Apr. 25. 2006;174(9):1263-4. [pmid: 16636325].
131 Bolognini S, Orsini V, Grandinetti PP, et al. Lichtenstein vs. Rutkow-Robbins technique in the treatment of primary inguinal hernia. Analysis of the long term results. Ann Ital Chir. Jan-Feb. 2006;77(1):51-6. [pmid: 16910360].
132 Guner A, Guler K, Bozkurt S, et al. Anterior Lichtenstein repair versus posterior preperitoneal repair techniques for recurrent inguinal hernia. Erciyes Tip Derg. 2009;31(1):037-43.
133 Sarli L, Pietra N, Choua O, et al. Laparoscopic hernia repair: a prospective comparison of TAPP and IPOM techniques. Surg Laparosc Endosc. Dec. 1997;7(6):472-6. [pmid: 9438629].
134 Zhang H, Lin J, Liao Q, et al. Totally extraperitoneal laparoscopic hernioplasty: the optimal surgical approach. Surg Laparosc Endosc Percutan Tech. Dec. 2009;19(6):501-5. [pmid: 20027096].
135 Dedemadi G, Sgourakis G, Karaliotas C, et al. Comparison of laparoscopic and open tension-free repair of recurrent inguinal hernias: a prospective randomized study. Surg Endosc. Jul. 2006;20(7):1099-104. [pmid: 16763926].
136 Mesci A, Korkmaz B, Dinckan A, et al. Digital evaluation of the muscle functions of the lower extremities among inguinal hernia patients treated using three different surgical techniques: a prospective randomized study. Surg Today. 2011. Nov. 3. [pmid: 22045231].
137 Krishna A, Misra MC, Bansal VK, et al. Laparoscopic inguinal hernia repair: transabdominal preperitoneal (TAPP) versus totally extraperitoneal (TEP) approach: a prospective randomized controlled trial. Surg Endosc. 2011. Sep. 30. [pmid: 21959688].
138 Pracki W. Laparoscopic and endoscopic inguinal hernia repair. Pol Przegl Chir. 2002;74(12):1145-56.
139 Mohamed H, Ion D, Serban MB, et al. Selecting criteria for the right prosthesis in defect of the abdominal wall surgery. J Med Life. Jul-Sep. 2009;2(3):249-53. Also available: http://www.medandlife.ro/medandlife267.html. [pmid: 20112467].
140 Robinson TN, Clarke JH, Schoen J, et al. Major mesh-related complications following hernia repair: events reported to the Food and Drug Administration. Surg Endosc. Dec. 2005;19(12):1556-60. Also available: http://www.surgery.ufl.edu/residency/Files/Mesh_complications_reported_to_FDA.pdf. [pmid: 16211441].
141 Polish Hernia Study Group, Smietanski M. Randomized clinical trial comparing a polypropylene with a poliglecaprone and polypropylene composite mesh for inguinal hernioplasty. Br J Surg. Dec. 2008;95(12):1462-8. [pmid: 18991255].
142 Bittner R, Leibl BJ, Kraft B, et al. One-year results of a prospective, randomised clinical trial comparing four meshes in laparoscopic inguinal hernia repair (TAPP). Hernia. Oct. 2011;15(5):503-10. [pmid: 21461904].
143 Bittner R, Schmedt CG, Leibl BJ, et al. Early postoperative and one year results of a randomized controlled trial comparing the impact of extralight titanized polypropylene mesh and traditional heavyweight polypropylene mesh on pain and seroma production in laparoscopic hernia repair (TAPP). World J Surg. Aug. 2011;35(8):1791-7. [pmid: 21607821].
144 Agarwal BB, Agarwal KA, Mahajan KC. Prospective double-blind randomized controlled study comparing heavy- and lightweight polypropylene mesh in totally extraperitoneal repair of inguinal hernia: early results. Surg Endosc. Feb. 2009;23(2):242-7. [pmid: 18923870].
145 Nikkolo C, Lepner U, Murruste M, et al. Randomised clinical trial comparing lightweight mesh with heavyweight mesh for inguinal hernioplasty. Hernia. Jun. 2010;14(3):253-8. [pmid: 20091327].
146 Paajanen H. A single-surgeon randomized trial comparing three composite meshes on chronic pain after Lichtenstein hernia repair in local anesthesia. Hernia. Aug. 2007;11(4):335-9. [pmid: 17492341].
147 Paradowski T, Olejarz A, Kontny T, et al. Polypropylene vs. ePTFE vs. WN mesh for Lichtenstein inguinal hernia repair - A prospective randomized, double blind pilotstudy of one-year follow-up. Wideochir I Inne Tech Maloinwazyjne. 2009;4(1):6-9.
148 Bringman S, Wollert S, Osterberg J, et al. Early results of a randomized multicenter trial comparing Prolene and VyproII mesh in bilateral endoscopic extraperitoneal hernioplasty (TEP). Surg Endosc. Apr. 2005;19(4):536-40. [pmid: 15759178].
149 Chowbey PK, Garg N, Sharma A, et al. Prospective randomized clinical trial comparing lightweight mesh and heavyweight polypropylene mesh in endoscopic totally extraperitoneal groin hernia repair. Surg Endosc. Dec. 2010;24(12):3073-9. [pmid: 20490567].
150 Peeters E, Spiessens C, Oyen R, et al. Laparoscopic inguinal hernia repair in men with lightweight meshes may significantly impair sperm motility: a randomized controlled trial. Ann Surg. Aug. 2010;252(2):240-6. [pmid: 20622657].
151 Heikkinen T, Wollert S, Osterberg J, et al. Early results of a randomised trial comparing Prolene and VyproII-mesh in endoscopic extraperitoneal inguinal hernia repair (TEP) of recurrent unilateral hernias. Hernia. Mar. 2006;10(1):34-40. [pmid: 16088358].
152 Bringman S, Heikkinen TJ, Wollert S, et al. Early results of a single-blinded, randomized, controlled, Internet-based multicenter trial comparing Prolene and Vypro II mesh in Lichtenstein hernioplasty. Hernia. May. 2004;8(2):127-34. [pmid: 14648244].
153 Bringman S, Wollert S, Osterberg J, et al. One year results of a randomised controlled multi-centre study comparing Prolene and Vypro II-mesh in Lichtenstein hernioplasty. Hernia. Oct. 2005;9(3):223-7. [pmid: 16450078].
154 Bringman S, Wollert S, Osterberg J, et al. Three-year results of a randomized clinical trial of lightweight or standard polypropylene mesh in Lichtenstein repair of primary inguinal hernia. Br J Surg. Sep. 2006;93(9):1056-9. [pmid: 16862613].
155 Di Vita G, Patti R, Barrera T, et al. Impact of heavy polypropylene mesh and composite light polypropylene and polyglactin 910 on the inflammatory response. Surg Innov. Sep. 2010;17(3):229-35. [pmid: 20798094].
156 O'Dwyer PJ, Kingsnorth AN, Molloy RG, et al. Randomized clinical trial assessing impact of a lightweight or heavyweight mesh on chronic pain after inguinal hernia repair. Br J Surg. Feb. 2005;92(2):166-70. [pmid: 15584057].
157 Post S, Weiss B, Willer M, et al. Randomized clinical trial of lightweight composite mesh for Lichtenstein inguinal hernia repair. Br J Surg. Jan. 2004;91(1):44-8. [pmid: 14716792].
158 Puccio F, Solazzo M, Marciano P. Comparison of three different mesh materials in tension-free inguinal hernia repair: prolene versus Vypro versus surgisis. Int Surg. Jul-Aug. 2005;90(3 Suppl):S21-3. [pmid: 16463943].
159 Langenbach MR, Schmidt J, Zirngibl H. Comparison of biomaterials: three meshes and TAPP for inguinal hernia. Surg Endosc. Oct. 2006;20(10):1511-7. [pmid: 16915511].
160 Langenbach MR, Schmidt J, Ubrig B, et al. Sixty-month follow-up after endoscopic inguinal hernia repair with three types of mesh: a prospective randomized trial. Surg Endosc. Aug. 2008;22(8):1790-7. [pmid: 18398650].
161 Champault G, Bernard C, Rizk N, et al. Inguinal hernia repair: the choice of prosthesis outweighs that of technique. Hernia. Apr. 2007;11(2):125-8. [pmid: 17216121].
162 Khan N, Bangash A, Sadiq M, et al. Polyglactine/polypropylene mesh vs. propylene mesh: is there a need for newer prosthesis in inguinal hernia?. Saudi J Gastroenterol. Jan-Mar. 2010;16(1):8-13. [pmid: 20065567].
163 Torcivia A, Vons C, Barrat C, et al. Influence of mesh type on the quality of early outcomes after inguinal hernia repair in ambulatory setting controlled study: Glucamesh(R) vs Polypropylene(R). Langenbecks Arch Surg. 2010. Nov. 9.
164 Chauhan A, Tiwari S, Gupta A. Study of efficacy of bilayer mesh device versus conventional polypropelene hernia system in inguinal hernia repair: early results. World J Surg. Jun. 2007;31(6):1356-9. discussion 1360-1. [pmid: 17437156].
165 Sutalo N, Maricic A, Kozomara D, et al. Comparison of results of surgical treatments of primary inguinal hernia with flat polypropylene mesh and three-dimensional prolene (Phs) mesh--one year follow up. Coll Antropol. Mar. Suppl 1. 2010;34:129-33. [pmid: 20402308].
166 Ansaloni L, Catena F, Coccolini F, et al. Inguinal hernia repair with porcine small intestine submucosa: 3-year follow-up results of a randomized controlled trial of Lichtenstein's repair with polypropylene mesh versus Surgisis Inguinal Hernia Matrix. Am J Surg. Sep. 2009;198(3):303-12. [pmid: 19285658].
167 Ansaloni L, Catena F, D'Alessandro L. Prospective randomized, double-blind, controlled trial comparing Lichtenstein's repair of inguinal hernia with polypropylene mesh versus Surgisis gold soft tissue graft: preliminary results. Acta Biomed. Suppl 2. 2003;74:10-4. [pmid: 15055026].
168 Gundre NP, Iyer SP, Subramaniyan P. Prospective randomized controlled study using polyethylene mesh for inguinal hernia meshplasty as a safe and cost-effective alternative to polypropylene mesh. Updates Surg. 2011. Aug. 18. [pmid: 21850553].
169 Sadowski B, Rodriguez J, Symmonds R, et al. Comparison of polypropylene versus polyester mesh in the Lichtenstein hernia repair with respect to chronic pain and discomfort. Hernia. 2011. Jul. 14. [pmid: 21755316].
170 Chui LB, Ng WT, Sze YS, et al. Prospective, randomized, controlled trial comparing lightweight versus heavyweight mesh in chronic pain incidence after TEP repair of bilateral inguinal hernia. Surg Endosc. 2010. Apr. 8. [pmid: 20376498].
171 Schopf S, von Ahnen T, von Ahnen M, et al. Chronic pain after laparoscopic transabdominal preperitoneal hernia repair: a randomized comparison of light and extralight titanized polypropylene mesh. World J Surg. Feb. 2011;35(2):302-10. [pmid: 21103989].
172 Freudenberg S, Sano D, Ouangre E, et al. Commercial mesh versus Nylon mosquito net for hernia repair. A randomized double-blind study in Burkina Faso. World J Surg. Oct. 2006;30(10):1784-9. dicussion 1790. [pmid: 16983472].
173 DeBord JR, Bauer JJ, Grischkan DM, et al. Short-term study on the safety of antimicrobial-agent-impregnated ePTFE patches for hernia repair. Hernia. Dec. 1999;3(4):189-93.
174 Koch A, Bringman S, Myrelid P, et al. Randomized clinical trial of groin hernia repair with titanium-coated lightweight mesh compared with standard polypropylene mesh. Br J Surg. Oct. 2008;95(10):1226-31. [pmid: 18763243].
175 Langenbach MR, Schmidt J, Zirngibl H. Comparison of biomaterials in the early postoperative period. Surg Endosc. Jul. 2003;17(7):1105-9. [pmid: 12728375].
176 Sun X, Lin FC, Li G, et al. Two kinds of biopatches in tension-free hernia repair in 57 cases: comparison of complications and preventive measures. J Clin Rehabil Tiss Eng Res. Dec. 2. 2008;12(49):9751-4.
177 Langenbach MR, Schmidt J, Lazika M, et al. Urological symptoms after laparoscopic hernia repair. Reduction with a variant of polypropylene mesh. Urologe A. Mar. 2003;42(3):375-81. [pmid: 12671771].
178 Wang HP, Tian XL, Guo Y. Comparison of two different prosthetic materials in the treatment of inguinal hernia in aged patients. J Clin Rehabil Tiss Eng Res. Nov. 4. 2008;12(45):8881-4.
179 Fortelny RH, Petter-Puchner AH, May C, et al. The impact of atraumatic fibrin sealant vs. staple mesh fixation in TAPP hernia repair on chronic pain and quality of life: results of a randomized controlled study. Surg Endosc. 2011. Aug. 19. [pmid: 21853390].
180 Koch CA, Greenlee SM, Larson DR, et al. Randomized prospective study of totally extraperitoneal inguinal hernia repair: fixation versus no fixation of mesh. JSLS. Oct-Dec. 2006;10(4):457-60. [pmid: 17575757].
181 Taylor C, Layani L, Liew V, et al. Laparoscopic inguinal hernia repair without mesh fixation, early results of a large randomised clinical trial. Surg Endosc. Mar. 2008;22(3):757-62. [pmid: 17885789].
182 Moreno-Egea A, Torralba Martinez JA, Morales Cuenca G, et al. Randomized clinical trial of fixation vs nonfixation of mesh in total extraperitoneal inguinal hernioplasty. Arch Surg. Dec. 2004;139(12):1376-9. [pmid: 15611465].
183 Parshad R, Kumar R, Hazrah P, et al. A randomized comparison of the early outcome of stapled and unstapled techniques of laparoscopic total extraperitoneal inguinal hernia repair. JSLS. Oct-Dec. 2005;9(4):403-7. [pmid: 16381354].
184 Smith AI, Royston CM, Sedman PC. Stapled and nonstapled laparoscopic transabdominal preperitoneal (TAPP) inguinal hernia repair. A prospective randomized trial. Surg Endosc. Aug. 1999;13(8):804-6. [pmid: 10430690].
185 Ferzli GS, Frezza EE, Pecoraro AM Jr, et al. Prospective randomized study of stapled versus unstapled mesh in a laparoscopic preperitoneal inguinal hernia repair. J Am Coll Surg. May. 1999;188(5):461-5. [pmid: 10235572].
186 Garg P, Nair S, Menon GR, et al. Mesh fixation compared to non-fixation in total extraperitoneal inguinal hernia repair: a randomized controlled trial in a rural center in India. Surg Endosc. Mar. 2011;25:3300-6. [pmid: 21533969].
187 Lau H. Fibrin sealant versus mechanical stapling for mesh fixation during endoscopic extraperitoneal inguinal hernioplasty: a randomized prospective trial. Ann Surg. Nov. 2005;242(5):670-5. [pmid: 16244540].
188 Boldo E, Armelles A, Perez de Lucia G, et al. Pain after laparascopic bilateral hernioplasty: early results of a prospective randomized double-blind study comparing fibrin versus st. Surg Endosc. May. 2008;22(5):1206-9. [pmid: 17943371].
189 Lovisetto F, Zonta S, Rota E, et al. Use of human fibrin glue (Tissucol) versus staples for mesh fixation in laparoscopic transabdominal preperitoneal hernioplasty: a prospective, randomized study. Ann Surg. Feb. 2007;245(2):222-31. [pmid: 17245175].
190 Olmi S, Scaini A, Erba L, et al. Quantification of pain in laparoscopic transabdominal preperitoneal (TAPP) inguinal hernioplasty identifies marked differences between prosthesis fixation systems. Surgery. Jul. 2007;142(1):40-6. [pmid: 17629999].
191 Douglas JM, Young WN, Jones DB. Lichtenstein inguinal herniorrhaphy using sutures versus tacks. Hernia. Sep. 2002;6(3):99-101. [pmid: 12209296].
192 Mills IW, McDermott IM, Ratliff DA. Prospective randomized controlled trial to compare skin staples and polypropylene for securing the mesh in inguinal hernia repair. Br J Surg. Jun. 1998;85(6):790-2. [pmid: 9667709].
193 Leibl BJ, Kraft B, Redecke JD, et al. Are postoperative complaints and complications influenced by different techniques in fashioning and fixing the mesh in transperitoneal laparoscopic hernioplasty? Results of a prospective randomized trial. World J Surg. Dec. 2002;26(12):1481-4. [pmid: 12297933].
194 Helbling C, Schlumpf R. Sutureless Lichtenstein: first results of a prospective randomised clinical trial. Hernia. Jun. 2003;7(2):80-4. [pmid: 12820029].
195 Nowobilski W, Dobosz M, Wojciechowicz T, et al. Lichtenstein inguinal hernioplasty using butyl-2-cyanoacrylate versus sutures. Preliminary experience of a prospective randomized trial. Eur Surg Res. Nov-Dec. 2004;36(6):367-70. [pmid: 15591746].
196 Kapischke M, Schulze H, Caliebe A. Self-fixating mesh for the Lichtenstein procedure--a prestudy. Langenbecks Arch Surg. Apr. 2010;395(4):317-22. [pmid: 20174819].
197 Testini M, Lissidini G, Poli E, et al. A single-surgeon randomized trial comparing sutures, N-butyl-2-cyanoacrylate and human fibrin glue for mesh fixation during primary inguinal hernia repair. Can J Surg. Jun. 2010;53(3):155-60. [pmid: 20507786].
198 Kim-Fuchs C, Angst E, Vorburger S, et al. Prospective randomized trial comparing sutured with sutureless mesh fixation for Lichtenstein hernia repair: long-term results. Hernia. 2011. Jul. 26. [pmid: 21789654].
199 Paajanen H, Kossi J, Silvasti S, et al. Randomized clinical trial of tissue glue versus absorbable sutures for mesh fixation in local anaesthetic Lichtenstein hernia repair. Br J Surg. Sep. 2011;98(9):1245-51. [pmid: 21710480].
200 Wong JU, Leung TH, Huang CC, et al. Comparing chronic pain between fibrin sealant and suture fixation for bilayer polypropylene mesh inguinal hernioplasty: a randomized clinical trial. Am J Surg. Jul. 2011;202(1):34-8. [pmid: 21601822].
201 Paajanen H. Do absorbable mesh sutures cause less chronic pain than nonabsorbable sutures after Lichtenstein inguinal herniorraphy. Hernia. Mar. 2002;6(1):26-8. [pmid: 12090577].
202 Canonico S, Sciaudone G, Pacifico F, et al. Inguinal hernia repair in patients with coagulation problems: prevention of postoperative bleeding with human fibrin glue. Surgery. Mar. 1999;125(3):315-7. [pmid: 10076616].
203 Kuttel JC, Peterli R, Schupfer C, et al. Early results of transversalis-plasty. A prospective randomized comparison of non-resorbable and resorbable sutures. Helv Chir Acta. May. 1991;57(6):931-4. [pmid: 1909693].
204 Bittner R, Schmedt CG, Schwarz J, et al. Laparoscopic transperitoneal procedure for routine repair of groin hernia. Br J Surg. Aug. 2002;89(8):1062-6. [pmid: 12153636].
205 Bittner R. Laparoscopic surgery - 15 years after clinical introduction. World J Surg. Jul. 2006;30(7):1190-203. [pmid: 16816898].
206 Leibl BJ, Schmedt CG, Schwarz J, et al. A single institution's experience with transperitoneal laparoscopic hernia repair. Am J Surg. Jun. 1998;175(6):446-52. [pmid: 9645770].
207 Wauschkuhn CA, Schwarz J, Bittner R. Laparoscopic transperitoneal inguinal hernia repair (TAPP) after radical prostatectomy: is it safe? Results of prospectively collected data of more than 200 cases. Surg Endosc. May. 2009;23(5):973-7. [pmid: 19118418].
208 Leibl BJ, Schmedt CG, Kraft K, et al. Recurrence after endoscopic transperitoneal hernia repair (TAPP): causes, reparative techniques, and results of the reoperation. J Am Coll Surg. Jun. 2000;190(6):651-5. [pmid: 10872999].
209 Bobrzynski A, Budzynski A, Biesiada Z, et al. Experience--the key factor in successful laparoscopic total extraperitoneal and transabdominal preperitoneal hernia repair. Hernia. Jun. 2001;5(2):80-3. [pmid: 11505653].
210 Cheah WK, So JB, Lomanto D. Endoscopic extraperitoneal inguinal hernia repair: a series of 182 repairs. Singapore Med J. Jun. 2004;45(6):267-70. [pmid: 15181520].
211 Davies NM, Dunn DC, Appleton B, et al. Experience with 300 laparoscopic inguinal hernia repairs with up to 3 years follow-up. Ann R Coll Surg Engl. Nov. 1995;77(6):409-12. [pmid: 8540657].
212 Dunn DC, Wijesinghe LD, Pollard SG, et al. Post-operative rehabilitation following laparoscopic inguinal hernia repair. Minim Invasive Ther. 1994;3(3):159-62.
213 Dulucq JL, Wintringer P, Mahajna A. Laparoscopic totally extraperitoneal inguinal hernia repair: lessons learned from 3,100 hernia repairs over 15 years. Surg Endosc. Mar. 2009;23(3):482-6. [pmid: 18810548].
214 Edwards CC 2nd, Bailey RW. Laparoscopic hernia repair: the learning curve. Surg Laparosc Endosc Percutan Tech. Jun. 2000;10(3):149-53. [pmid: 10872976].
215 Feliu-Pala X, Martin-Gomez M, Morales-Conde S, et al. The impact of the surgeon's experience on the results of laparoscopic hernia repair. Surg Endosc. Dec. 2001;15(12):1467-70. [pmid: 11965467].
216 Ferzli G, Kiel T. Evolving techniques in endoscopic extraperitoneal herniorrhaphy. Surg Endosc. Aug. 1995;9(8):928-30. [pmid: 8525452].
217 Geis WP, Crafton WB, Novak MJ, et al. Laparoscopic herniorrhaphy: results and technical aspects in 450 consecutive procedures. Surgery. Oct. 1993;114(4):765-72. discussion 772-4. [pmid: 8211692].
218 Kapiris SA, Brough WA, Royston CM, et al. Laparoscopic transabdominal preperitoneal (TAPP) hernia repair. A 7-year two-center experience in 3017patients. Surg Endosc. Sep. 2001;15(9):972-5. [pmid: 11605111].
219 Kieturakis MJ, Nguyen DT, Vargas H, et al. Balloon dissection facilitated laparoscopic extraperitoneal hernioplasty. Am J Surg. Dec. 1994;168(6):603-7. discussion 607-8. [pmid: 7978004].
220 Lal P, Kajla RK, Chander J, et al. Laparoscopic total extraperitoneal (TEP) inguinal hernia repair: overcoming the learning curve. Surg Endosc. Apr. 2004;18(4):642-5. [pmid: 15026913].
221 Lau H, Patil NG, Yuen WK, et al. Learning curve for unilateral endoscopic totally extraperitoneal (TEP) inguinal hernioplasty. Surg Endosc. Dec. 2002;16(12):1724-8. [pmid: 12098025].
222 Liem MS, van der Graaf Y, van Steensel CJ, et al. Comparison of conventional anterior surgery and laparoscopic surgery for inguinal-hernia repair. N Engl J Med. May. 29. 1997;336(22):1541-7. [pmid: 9164809].
223 Liem MS, van Duyn EB, van der Graaf Y, et al. Recurrences after conventional anterior and laparoscopic inguinal hernia repair: a randomized comparison. Ann Surg. Jan. 2003;237(1):136-41. [pmid: 12496541].
224 Liem MS, Halsema JA, van der Graaf Y, et al. Cost-effectiveness of extraperitoneal laparoscopic inguinal hernia repair: a randomized comparison with conventional herniorrhaphy. Coala trial group. Ann Surg. Dec. 1997;226(6):668-75. discussion 675-6. [pmid: 9409566].
225 Liem MS, van Steensel CJ, Boelhouwer RU, et al. The learning curve for totally extraperitoneal laparoscopic inguinal hernia repair. Am J Surg. Feb. 1996;171(2):281-5. [pmid: 8619468].
226 Liem MS, van der Graaf Y, van Steensel CJ, et al. Faster recovery and fewer recurrences after laparoscopic than after conventional inguinal hernia surgery; a prospective randomized study. Nederlands Tijdschrift Voor Geneeskunde. 1997;141(29):1430-6.
227 Liem MS, van der Graaf Y, Zwart RC, et al. A randomised comparison of physical performance following laparoscopic and open inguinal hernia repair. Br J Surg. 1997;84:64-7. [pmid: 9043455].
228 Pikoulis E, Tsigris C, Diamantis T, et al. Laparoscopic preperitoneal mesh repair or tension-free mesh plug technique? A prospective study of 471 patients with 543 inguinal hernias. Eur J Surg. 2002;168(11):587-91. [pmid: 12699093].
229 Ramshaw B, Shuler FW, Jones HB, et al. Laparoscopic inguinal hernia repair: lessons learned after 1224 consecutive cases. Surg Endosc. Jan. 2001;15(1):50-4. [pmid: 11178763].
230 Schultz C, Baca I, Gotzen V. Laparoscopic inguinal hernia repair. Surg Endosc. Jun. 2001;15(6):582-4. [pmid: 11591945].
231 Swadia ND. Laparoscopic totally extra-peritoneal inguinal hernia repair: 9 year's experience. Hernia. 2011. Feb. 3. [pmid: 21290156].
232 Tamme C, Scheidbach H, Hampe C, et al. Totally extraperitoneal endoscopic inguinal hernia repair (TEP). Surg Endosc. Feb. 2003;17(2):190-5. [pmid: 12457220].
233 Voitk AJ. The learning curve in laparoscopic inguinal hernia repair for the community general surgeon. Can J Surg. Dec. 1998;41(6):446-50. [pmid: 9854534].
234 Zendejas B, Onkendi EO, Brahmbhatt RD, et al. Long-term outcomes of laparoscopic totally extraperitoneal inguinal hernia repairs performed by supervised surgical trainees. Am J Surg. Mar. 2011;201(3):379-83. discussion 383-4. [pmid: 21367383].
235 Kanakala V, Bawa S, Gallagher P, et al. Outcome of patients in laparoscopic training courses compared to standard patients. Surgeon. Jun. 2010;8(3):132-5. [pmid: 20400021].
236 Felix E, Scott S, Crafton B, et al. Causes of recurrence after laparoscopic hernioplasty. A multicenter study. Surg Endosc. Mar. 1998;12(3):226-31. [pmid: 9502701].
237 Dzielicki J, Korlacki W, Scierski A, et al. Laparoscopic total extraperitoneal inguinal hernia repair - The role of the expert in the learning curve. Wideochir I Inne Tech Maloinwazyjne. 2008;3(4):172-8.
238 Batorfi J. The treatment of inguinofemoral hernias with laparoscopic herniorraphy. Our experience of 1210 transabdominal preperitoneal (TAPP) reconstructions. Magy Seb. Dec. 2005;58(6):385-97. [pmid: 16550800].
239 Nahrstedt U, Niebuhr H, Hollmann S, et al. Laparoscopic hernioplasty - Results and complications. Chir Gastroenterol Interdiszip Gesprach. Mar. 1997;13(1):67-72.
240 Batorfi J, Kovacs V, Sandor J, et al. New possibility in inguino-femoral hernia repair: laparoscopic herniaplasty. Orv Hetil. Jun. 23. 1996;137(25):1359-62. [pmid: 8757083].
241 Stancanelli V, Perrucci A, Grandi U. Laparoscopic treatment of inguinal hernia. Two-year experience. Chirurgia. 1994;7(7-8):451-60.
242 Pironi D, Palazzini G, Panarese A, et al. Open mesh technique versus laparoscopic transabdominal preperitoneal (TAPP) approach in inguinal hernia repair. Our experience. G Chir. Nov-Dec. 2008;29(11-12):497-504. [pmid: 19068188].
243 Leibl BJ, Schmedt CG, Ulrich M, et al. Laparoscopic hernia therapy (TAPP) as a teaching operation. Chirurg. Aug. 2000;71(8):939-42. discussion 943. [pmid: 11013814].
244 Gerber S, Hammerli PA, Glattli A. Laparoscopic transabdominal preperitoneal hernioplasty. Evaluation of complications due to transabdominal approach. Chirurg. Jul. 2000;71(7):824-8. [pmid: 10986605].
245 Barrat C, Voreux JP, Occelli G, et al. Effects of surgical education and training on the results of laparoscopic treatment of inguinal hernias. Chirurgie. Jun. 1999;124(3):298-303. [pmid: 10429304].
246 Bittner R, Kraft K, Schmedt CG, et al. Risks and benefits of laparoscopic hernia-plasty (TAPP). 5 years experiences with 3,400 hernia repairs. Chirurg. Aug. 1998;69(8):854-8. [pmid: 9782402].
247 Sievers D, Barkhausen S, Scheer H, et al. Laparoscopic transperitoneal inguinal hernia repair (TAPP)--complications and results of a prospective study. Langenbecks Arch Chir Suppl Kongressbd. 1997;114:1116-8. [pmid: 9574351].
248 Freund HR, Seror D, Eimerl D, et al. Preliminary experience with laparoscopic repair of inguinal hernias. Harefuah. Dec. 1. 1997;133(11):524-7. [pmid: 9451891].
249 Starzewski J, Szczerba K, Hyla K, et al. Late results of laparoscopic surgery for inguinal hernia (TAPP). Wiad Lek. 1997;50(Suppl 1 Pt 1):402-4. [pmid: 9446394].
250 Johanet H, Cossa JP, Marmuse JP, et al. Treatment of inguinal hernia by laparoscopy. Four-year results of the transpreperitoneal approach. Ann Chir. 1996;50(9):790-4. [pmid: 9124786].
251 Leibl B, Schwarz J, Däubler P, et al. Endoscopic hernia surgery (TAPP)--gold standard in management of recurrent hernias?. Chirurg. Dec. 1996;67(12):1226-30. [pmid: 9081784].
252 Bittner R, Leibl B, Kraft K, et al. Laparoscopic hernioplasty (TAPP)--complications and recurrences in 900 operations. Zentralbl Chir. 1996;121(4):313-9. [pmid: 8677687].
253 Neufang T, Lepsien G. Laparoscopic hernioplasty. Zentralbl Chir. 1994;119(6):432-44. [pmid: 8091881].
254 Chan KL, Hui WC, Tam PK. Prospective randomized single-center, single-blind comparison of laparoscopic vs open repair of pediatric inguinal hernia. Surg Endosc. Jul. 2005;19(7):927-32. [pmid: 15920685].
255 Koivusalo AI, Korpela R, Wirtavuori K, et al. A single-blinded, randomized comparison of laparoscopic versus open hernia repair in children. Pediatrics. Jan. 2009;123(1):332-7. [pmid: 19117900].
256 Swanstrom LL. Laparoscopic herniorrhaphy. Surg Clin North Am. 1996;76(3):483-91. [pmid: 8669008].
257 DeTurris SV, Cacchione RN, Mungara A, et al. Laparoscopic herniorrhaphy: beyond the learning curve. J Am Coll Surg. Jan. 2002;194(1):65-73. [pmid: 11800341].
258 Lotan G, Efrati Y, Stolero S, et al. Transinguinal laparoscopic examination: an end to the controversy on repair of inguinal hernia in children. Isr Med Assoc J. Jun. 2004;6(6):339-41. [pmid: 15214460].
259 Lee SL, Sydorak RM, Lau ST. Laparoscopic contralateral groin exploration: is it cost effective?. J Pediatr Surg. Apr. 2010;45(4):793-5. [pmid: 20385289].
260 Steinau G, Dreuw B, Schleef J, et al. Recommendations for treatment of contralateral inguinal hernias in children. Hernia. 1999;3(2):53-6.
261 Toufiqu Ehsane M, Ng AT, Chung PH, et al. Laparoscopic hernioplasties in children: the implication on contralateral groin exploration for unilateral inguinal hernias. Pediatr Surg Int. Sep. 2009;25(9):759-62. [pmid: 19652984].
262 Eller Miranda M, Duarte Lanna JC. Videolaparoscopy of the contralateral internal inguinal ring via the hernia sac in children with unilateral inguinal hernia-initial experience in Brazil, with a meta-analysis. Pediatr Surg Int. Sep. 2002;18(5-6):463-9. [pmid: 12415382].
263 Zampieri N, Zuin V, Ottolenghi A, et al. Contralateral exploration for unilateral inguinal hernia in females: risk factors and surgical findings. Hernia. 2008;12(5):511-4. [pmid: 18496730].
264 Surana R, Puri P. Is contralateral exploration necessary in infants with unilateral inguinal hernia?. J Pediatr Surg. Aug. 1993;28(8):1026-7. [pmid: 8229590].
265 Ballantyne A, Jawaheer G, Munro FD. Contralateral groin exploration is not justified in infants with a unilateral inguinal hernia. Br J Surg. May. 2001;88(5):720-3. [pmid: 11350448].
266 Ulman I, Demircan M, Arikan A, et al. Unilateral inguinal hernia in girls: is routine contralateral exploration justified?. J Pediatr Surg. Dec. 1995;30(12):1684-6. [pmid: 8749924].
267 Dick AC, Deans GT, Irwin ST. A prospective study of adult inguinal hernia repairs using absorbable sutures. J R Coll Surg Edinb. Oct. 1996;41(5):319-20. [pmid: 8908956].
268 Schwobel MG, Schramm H, Gitzelmann CA. The infantile inguinal hernia - a bilateral disease?. Pediatr Surg Int. 1999;15(2):115-8. [pmid: 10079343].
269 Rosen M, Garcia-Ruiz A, Malm J, et al. Laparoscopic hernia repair enhances early return of physical work capacity. Surg Laparosc Endosc Percutan Tech. Feb. 2001;11(1):28-33. [pmid: 11269552].
270 Nazir M, Saebø A. Contralateral inguinal hernial development and ipsilateral recurrence following unilateral hernial repair in infants and children. Acta Chir Belg. Feb. 1996;96(1):28-30. [pmid: 8629384].
271 Velanovich V, Shadduck P, Khaitan L, et al. Analysis of the SAGES Outcomes Initiative groin hernia database. Surg Endosc. Feb. 2006;20(2):191-8. [pmid: 16341567].
272 Marappan S, Veitch PS, Barrie WW, et al. Laparoscopic hernia repair in Leicester General Hospital: a prospective audit of 94 patients. Ann R Coll Surg Engl. Jul. 1996;78(4):359-62. [pmid: 8712651].