# Peer Reviewers

David Farley, M.D.

Mayo Clinic

Rochester, MN

Julian Losanoff, M.D.

Wayne State University School of Medicine

Detroit, MI

Leigh Neumayer, M.D.

University of Utah School of Medicine

Salt Lake City, UT

Patrick O’Dwyer, M.B., M.D., FRCS

University of Glasgow

Glasgow, Scotland, UK