# Key Informants

Gilles Bommart

Consumer

Don G. Goffena

W.L. Gore and Associates

Phoenix, AZ

KuoJen Tsao, M.D.

Assistant Professor of Pediatric Surgery

The University of Texas Health Science Center at Houston

Houston, TX

Guy Voeller, M.D., FACS

UT Medical Group

Germantown, TN