# Introduction

An inguinal hernia is a protrusion of abdominal contents into the inguinal canal through an abdominal wall defect. A direct inguinal hernia protrudes through the deep inguinal ring, whereas an indirect inguinal hernia protrudes through the internal inguinal ring and may descend through the inguinal canal. Direct hernias typically develop only in adulthood and are more likely to recur than indirect hernias.11 If the hernia is severe enough to restrict blood supply to the intestine, it is termed a strangulated hernia, and immediate corrective surgery is necessary. Most inguinal hernias, however, are less dangerous, and elective surgery is often performed to correct the defect. Symptoms include abdominal pain and a lump in the groin area, which is most easily palpable during a cough. Some inguinal hernias, however, are asymptomatic.12

The lifetime rate of inguinal hernia is 25 percent in males and 2 percent in females.1 The risk of inguinal hernia increases with age, and the annual incidence is around 50 percent in men by the age of 75.^2^ Approximately two-thirds of inguinal hernias are indirect, and one-third are direct.1 Approximately 10 percent of cases are bilateral.3 Recurrence occurs in about 1 percent to 5 percent of cases.8

In children, the incidence ranges from 0.8 percent to 4.4 percent.4 It is 10 times as common in boys as in girls and also more common in infants born before 32 weeks' gestation (13 percent prevalence) and infants weighing less than 1,000 grams at birth (30 percent prevalence).4 As in adults, about 10 percent of cases involve bilateral hernia.13

Numerous classification systems have been proposed for groin hernias.14 One commonly used system was introduced by Nyhus in 1993.^15^ This system employs several clinical factors including direct/indirect, degree of enlargement of the internal inguinal ring, and degree of posterior wall weakness. Specifically, it comprises six types of increasing severity: (1) indirect inguinal hernia with a normal internal ring; (2) indirect inguinal hernia with an enlarged internal ring; (3a) direct inguinal hernia; (3b) indirect inguinal hernia causing posterior wall weakness; (3c) femoral hernia; and (4) recurrent hernia.15 (This review will not involve femoral hernias because of the different patient populations and pertinent treatments.) Stoppa16 proposed that aggravating factors such as obesity or abdominal distension should upgrade the patient by one Nyhus level.16 Higher severity generally means a higher risk of recurrence, and an appropriate classification may support the management approach.

Surgical repair of hernias is the most commonly performed general surgical procedure in the United States.5 In 2003, an estimated 770,000 surgical repairs of inguinal hernia were performed.5 These repairs are typically performed on an outpatient basis (87 percent in 1996).5 This large volume of procedures suggests that even modest improvements in patient outcomes would have a substantial impact on population health.7 Most inguinal hernia repairs are conducted in an outpatient setting;5 Rutkow (2003)5 estimated that 87 percent were outpatient procedures in 1996 and the percentage has probably increased since then.

The primary goals of surgery include repairing the hernia, minimizing the chance of recurrence, returning the patient to normal activities quickly, and minimizing postsurgical discomfort and the adverse effects of surgery. The various surgeries present different constellations of benefits and risks, which presents some clinical uncertainty in the choice among approaches. Balancing these factors is a difficult yet critical process in an effort to make the best possible medical decisions.

Some patients with inguinal hernias may not be in pain or limited in any way by the hernia. For these patients, surgery may not be necessary. One of the Key Questions in the evidence review will be a comparison between surgical and nonsurgical approaches to the management of pain-free inguinal hernias.

Surgical procedures for inguinal hernia repair generally fall into three categories: open repair without the use of a mesh implant (i.e., sutured), open repair with a mesh, and laparoscopic repair with a mesh. Within each of these categories, several specific procedures have been employed. Until the 1980s, open suture repair was the standard; however, the resulting tension along the suture line yielded relatively high rates of recurrence and patient discomfort. Nonsutured “tension-free” surgical mesh gained in popularity, and many specific open procedures were used. One author estimates that in 2003, 93 percent of groin hernia repairs involved the use of a mesh, and of these, about three-fourths of these repairs involved either a Lichtenstein repair or mesh plug.5

In a Lichtenstein repair, surgeons suture the mesh in front of the hernia defect. In a mesh plug repair, surgeons introduce a preshaped mesh plug into the hernia weakness during open surgery and position a piece of flat mesh on top of the hernia defect. Kumar et al. (1999)17 suggested that Lichtension repair is appropriate for primary inguinal hernia and possibly also for large recurrent hernias. The mesh plug repair may require less dissection, and may reduce patients' postoperative discomfort, thereby quickening the return to “normal activity.”18-20 A possible disadvantage of the mesh plug repair may be related to hardening of the plug, resulting in pain in the groin region.18

The near universal adoption of mesh means that the most important questions about hernia repair involve various mesh procedures. A glossary of several other open repair procedures, as well as laparoscopic procedures, appears after the Reference section. Generally, mesh is not recommended for use in pediatric inguinal hernia because of concerns about the risk of inflammatory reactions, damage to the vas deferens and/or testes, and infertility.4

More recently, two laparoscopic approaches using a mesh—transabdominal preperitoneal (TAPP) repair and totally extraperitoneal (TEP) repair—have seen increased use.21 Transabdominal preperitoneal (TAPP) repair involves entering the peritoneal cavity to place a mesh through an incision over likely hernia sites. TEP technique does not involve entering the peritoneal cavity, and surgeons place the mesh used to cover the hernia from the outside of the peritoneum. Laparoscopic approaches have the potential for shortening recovery time and reducing some postoperative morbidities.22 They also may be associated with longer operation times and a relatively long learning curve. TEP was introduced after TAPP because of concerns about a possible increased risk of internal organ damage within the peritoneum. Laparoscopic repair invariably involves general anesthesia, whereas open mesh repair can involve any type of anesthesia.

Research has shown that the repair of a recurrent inguinal hernia is subject to a greater risk of recurrence.23 Further, bilateral inguinal hernia is subject to a greater recurrence risk than unilateral inguinal hernia.24 These increased risks may be due to certain anatomical difficulties that complicate the surgical approach in these types of patients.25 Some clinicians have suggested that laparoscopic approaches are better suited to recurrent and bilateral hernias, and in Key Question 2 (see below) we delineate separate comparisons for primary, bilateral, and recurrent hernia.

Specific aspects about mesh repair that may influence outcomes are the type of mesh (e.g., polypropylene (PP) or other material), whether mesh fixation is used, and if so, whether fixation is accomplished with sutures or glue. These mesh-specific issues are covered by specific Key Questions (see Key Questions below). The U.S. Food and Drug Administration has received reports of complications associated with mesh materials. The complications include adverse reactions to the mesh; adhesions (when the loops of the intestines adhere to each other or the mesh); and injuries to nearby organs, nerves or blood vessels. Other complications of hernia repair can occur with or without the mesh, including infection, chronic pain and hernia recurrence. Most of the complications reported to the FDA have been associated with mesh products that have been recalled and are no longer on the market.26

FDA recalled the Bard Composix® Kugel® Mesh Patch manufactured before October 2005 and stated “the mesh can break under the stress of placement inside the belly area.”27 Fourteen lot numbers of XenMatrix Surgical Graft were recalled as a result of “elevated endotoxin levels.”28 Lastly, 15 lot numbers of Bard Flat Mesh were recalled because “the material was counterfeit and did not meet the manufacturer's specifications.”29

Different procedures often require different methods for anesthesia. Some forms of open mesh repair can be performed with local anesthesia, whereas laparoscopic techniques such as TAPP typically require general anesthesia.9 Two key postsurgical morbidities are surgical site infection30 and chronic pain.31 Regarding chronic pain, Nienhuijs and colleagues31 estimated that pain lasting beyond 3 months postoperatively occurs in 11 percent of patients undergoing mesh repair.

In terms of settings, most hernia surgeries are performed not in specialized hernia centers, but rather by general surgeons who also perform many other types of surgeries.9 It is generally recognized that the surgical repair of inguinal hernia is a highly specialized skill, and patients receiving care from more-experienced surgeons may fare better than patients receiving care from less-experienced surgeons. The evidence review will specifically examine evidence on the association between surgical experience and hernia recurrence (RC) (see Key Questions below).

Given the clinical uncertainty, a systematic review of the existing evidence on comparative effectiveness will help inform important medical decisions about surgical options for inguinal hernia. The findings of the review may affect clinical decisions by patients and surgeons, treatment recommendations by professional societies, purchasing decisions by hospitals, and coverage decisions by payers.