# Glossary of Procedures

Open mesh procedures
Kugel patch repair: A hernia repair procedure wherein an oval-shaped mesh that is held open by a memory recoil ring is inserted behind the hernia defect and held in place with a single absorbable suture.
Lichtenstein technique: A tension-free open hernia repair procedure wherein mesh is sutured in front of the hernia defect (anteriorly)
Mesh plug technique: A hernia repair procedure wherein a preshaped mesh plug is introduced into the hernia weakness during open surgery and a piece of flat mesh is positioned on top of the hernia defect.
Open preperitoneal mesh (OPM) technique: A tension-free open hernia repair procedure wherein mesh is sutured posteriorly.
Prolene Hernia System (PHS): A one-piece mesh device constructed of an onlay patch connected to a circular underlay patch by a mesh cylinder.
Read-Rives repair: A tension-free hernia repair procedure where in mesh is placed just over the peritoneum.
Stoppa technique: A hernia repair wherein a large polyester mesh is interposed in the preperitoneal connective tissue between the peritoneum and transversalis fascia to prevent visceral sac extension through the myopectineal orifice.
Trabucco technique: A hernia repair procedure that involves placing a single preshaped mesh without using sutures.

Laparoscopic mesh procedures
Intraperitoneal onlay mesh (IPOM) technique: A hernia repair procedure wherein a mesh is placed over the hernia defect intra-abdominally to circumvent a groin dissection.
Totally extraperitoneal (TEP) technique: A laparoscopic hernia repair procedure wherein peritoneal cavity is not entered and a mesh is used to cover the hernia from the outside of the peritoneum.
Transabdominal preperitoneal (TAPP) technique: A laparoscopic hernia repair procedure that involves entering the peritoneal cavity to place a mesh through an incision over likely hernia sites.