# References for Appendixes B and C

1 Aasbo V, Thuen A, Raeder J. Improved long-lasting postoperative analgesia, recovery function and patient satisfaction after inguinal hernia repair with inguinal field block compared with general anesthesia. Acta Anaesthesiol Scand. Jul. 2002;46(6):674-8. [pmid: 12059890].
2 Aasvang E, Kehlet H. Chronic postoperative pain: the case of inguinal herniorrhaphy. Br J Anaesth. Jul. 2005;95(1):69-76. [pmid: 15531621].
3 Aeberhard P, Klaiber C, Meyenberg A, et al. Prospective audit of laparoscopic totally extraperitoneal inguinal hernia repair: a multicenter study of the Swiss Association for Laparoscopic and Thoracoscopic Surgery (SALTC). Surg Endosc. Nov. 1999;13(11):1115-20. [pmid: 10556450].
4 Agarwal BB, Agarwal KA, Sahu T, et al. Traditional polypropylene and lightweight meshes in totally extraperitoneal inguinal herniorrhaphy. Int J Surg. 2010;8(1):44-7. [pmid: 19853672].
5 Agresta F, Mazzarolo G, Bedin N. Inguinal hernia repair in a community hospital setting--have attitudes changed because of laparoscopy? A review of a general surgeon's experience over the last 5 years. Surg Laparosc Endosc Percutan Tech. Jun. 2009;19(3):267-71. [pmid: 19542860].
6 Aigner F, Augustin F, Kaufmann C, et al. Prospective, randomized-controlled trial comparing postoperative pain after open and minimal invasive inguinal hernia repair. Eur Surg. Jun. 2011;43(Suppl 241):39.
7 Aitola P, Airo I, Matikainen M. Laparoscopic versus open preperitoneal inguinal hernia repair: a prospective randomised trial. Ann Chir Gynaecol. 1998;87(1):22-5. [pmid: 9598225].
8 Akbulut G, Serteser M, Yucel A, et al. Can laparoscopic hernia repair alter function and volume of testis? Randomized clinical trial. Surg Laparosc Endosc Percutan Tech. Dec. 2003;13(6):377-81. [pmid: 14712099].
9 Akcaboy EY, Akcaboy ZN, Gogus N. Ambulatory inguinal herniorrhaphy: paravertebral block versus spinal anesthesia. Minerva Anestesiol. Dec. 2009;75(12):684-91. [pmid: 19940820].
10 Akhtar K, Kamalky-asl ID, Lamb WR, et al. Metabolic and inflammatory responses after laparoscopic and open inguinal hernia repair. Ann R Coll Surg Engl. Mar. 1998;80(2):125-30. [pmid: 9623379].
11 Akolekar D, Kumar S, Khan LR, et al. Comparison of recurrence with lightweight composite polypropylene mesh and heavyweight mesh in laparoscopic totally extraperitoneal inguinal hernia repair: an audit of 1,232 repairs. Hernia. Feb. 2008;12(1):39-43. [pmid: 17851728].
12 Alani A, Duffy F, O'Dwyer PJ. Laparoscopic or open preperitoneal repair in the management of recurrent groin hernias. Hernia. Apr. 2006;10(2):156-8. [pmid: 16341624].
13 Albright E, Diaz D, Davenport D, et al. The component separation technique for hernia repair: a comparison of open and endoscopic techniques. Am Surg. Jul. 2011;77(7):839-43. [pmid: 21944344].
14 Alfieri S, Rotondi F, Di Giorgio A, et al. Influence of preservation versus division of ilioinguinal, iliohypogastric, and genital nerves during open mesh herniorrhaphy: prospective multicentric study of chronic pain. Ann Surg. Apr. 2006;243(4):553-8. [pmid: 16552209].
15 Altinli E, Koksal N, Erdogan D, et al. Comparison of tep vs kugel vs lichtenstein hernia repair; prospective randomized trial. Surg Endosc. Mar. 2011;25:S9.
16 Amato B, Moja L, Panico S, et al. Shouldice technique versus other open techniques for inguinal hernia repair. Cochrane Database of Systematic Reviews. [internet]. Hoboken (NJ). John Wiley & Sons, Ltd. 2009;(4). 2010 Jul 2. [Art. No.: CD001543]. Available:. [doi: 10.1002/14651858.CD001543.pub3]. [pmid: 19821279].
17 Amid PK, Shulman AG, Lichtenstein IL. A critical comparison of laparoscopic hernia repair with Lichtenstein tension-free hernioplasty. Med J Aust. Aug. 15. 1994;161(4):239-41. [pmid: 8047029].
18 Amid PK, Shulman AG, Lichtenstein IL. Simultaneous repair of bilateral inguinal hernias under local anesthesia. Ann Surg. Mar. 1996;223(3):249-52. [pmid: 8604904].
19 Anadol AZ, Akin M, Kurukahvecioglu O, et al. A prospective comparative study of the efficacy of conventional Lichtenstein versus self-adhesive mesh repair for inguinal hernia. Surg Today. Nov. 2011;41(11):1498-503. [pmid: 21969152].
20 Andersen JR, Burcharth F, Larsen HW, et al. Polyglycolic acid, silk, and topical ampicillin. Their use in hernia repair and cholecystectomy. Arch Surg. Mar. 1980;115(3):293-5. [pmid: 6243916].
21 Andrew DR, Middleton SB, Richardson DR. A comparison of laparoscopic and open inguinal hernia repair in servicemen. J R Army Med Corps. Jun. 1994;140(2):76-8. [pmid: 8907834].
22 Antao B, Samuel M, Curry J, et al. Comparative evaluation of laparoscopic vs. open inguinal herniotomy in infants. Pediatr Endosurg Innov Tech. Dec. 2004;8(4):302-9.
23 Arregui ME, Young SB. Groin hernia repair by laparoscopic techniques: current status and controversies. World J Surg. Aug. 2005;29(8):1052-7. [pmid: 15983713].
24 Arvidsson D, Smedberg S. Laparoscopic compared with open hernia surgery: complications, recurrences and current trends. Eur J Surg Suppl. 2000;(585):40-7. [pmid: 10885557].
25 Arvidsson D, Berndsen FH, Larsson LG, et al. Randomized clinical trial comparing 5-year recurrence rate after laparoscopic versus Shouldice repair of primary inguinal hernia. Br J Surg. Sep. 2005;92(9):1085-91. [pmid: 16106480].
26 Atkinson HD, Nicol SG, Purkayastha S, et al. Surgical management of inguinal hernia: retrospective cohort study in southeastern Scotland, 1985-2001. BMJ. Dec. 4. 2004;329(7478):1315-6. [pmid: 15546894].
27 Aufenacker TJ, van Geldere D, van Mesdag T, et al. The role of antibiotic prophylaxis in prevention of wound infection after Lichtenstein open mesh repair of primary inguinal hernia: a multicenter double-blind randomized controlled trial. Ann Surg. Dec. 2004;240(6):955-60. discussion 960-1. [pmid: 15570201].
28 Awad SS, Yallampalli S, Srour AM, et al. Improved outcomes with the Prolene Hernia System mesh compared with the time-honored Lichtenstein onlay mesh repair for inguinal hernia repair. Am J Surg. Jun. 2007;193(6):697-701. [pmid: 17512279].
29 Aydede H, Erhan Y, Sakarya A, et al. Effect of mesh and its localisation on testicular flow and spermatogenesis in patients with groin hernia. Acta Chir Belg. Nov-Dec. 2003;103(6):607-10. [pmid: 14743569].
30 Aytac B, Cakar KS, Karamercan A. Comparison of Shouldice and Lichtenstein repair for treatment of primary inguinal hernia. Acta Chir Belg. Aug. 2004;104(4):418-21. [pmid: 15469153].
31 Babineau TJ, Becker J, Gibbons G, et al. The “cost” of operative training for surgical residents. Arch Surg. Apr. 2004;139(4):366-9. discussion 369-70. [pmid: 15078701].
32 Baca I, Gotzen V, Gerbatsch KP, et al. Laparoscopy in the treatment of inguinal hernias. Croat Med J. 1995;36(3):166-9.
33 Baca I, Schultz C, Gotzen V, et al. Laparoscopic inguinal hernia repair. A review of 2500 cases. Lomanto D, Kum CK, So JB, Goh PM, editors. Proceedings of the 7th World Congress of Endoscopic Surgery. 2000:425-30.
34 Balakrishnan S, Singhal T, Samdani T, et al. Laparoscopic inguinal hernia repair: over a thousand convincing reasons to go on. Hernia. 2008;12(5):493-8. [pmid: 18496729].
35 Ballantyne A, Jawaheer G, Munro FD. Contralateral groin exploration is not justified in infants with a unilateral inguinal hernia. Br J Surg. May. 2001;88(5):720-3. [pmid: 11350448].
36 Baltazar N, Johnston DW. Dexon versus conventional sutures in hernia repair. Can J Surg. Jul. 1976;19(4):341-2. [pmid: 949645].
37 Bar-Dayan A, Natour M, Bar-Zakai B, et al. Preperitoneal bupivacaine attenuates pain following laparoscopic inguinal hernia repair. Surg Endosc. Jul. 2004;18(7):1079-81. [pmid: 15156393].
38 Baris S, Karakaya D, Kelsaka E, et al. Comparison of fentanyl-bupivacaine or midazolam-bupivacaine mixtures with plain bupivacaine for caudal anaesthesia in children. Paediatr Anaesth. Feb. 2003;13(2):126-31. [pmid: 12562485].
39 Barkun JS, Wexler MJ, Hinchey EJ, et al. Laparoscopic versus open inguinal herniorrhaphy: preliminary results of a randomized controlled trial. Surgery. Oct. 1995;118(4):703-9. discussion 709-10. [pmid: 7570325].
40 Barkun JS, Keyser EJ, Wexler MJ, et al. Short-term outcomes in open vs. laparoscopic herniorrhaphy: confounding impact of worker's compensation on convalescence. J Gastrointest Surg. Nov-Dec. 1999;3(6):575-82. [pmid: 10554363].
41 Barrat C, Surlin V, Bordea A, et al. Management of recurrent inguinal hernias: a prospective study of 163 cases. Hernia. Sep. 2003;7(3):125-9. [pmid: 12690533].
42 Barth RJ Jr, Burchard KW, Tosteson A, et al. Short-term outcome after mesh or shouldice herniorrhaphy: a randomized, prospective study. Surgery. Feb. 1998;123(2):121-6. [pmid: 9481395].
43 Batorfi J, Kovacs V, Sandor J, et al. A new method to repair inguino-femoral hernias: laparoscopic hernioplasty. Acta Chir Hung. 1995-1996;35(1-2):159-67. [pmid: 8659234].
44 Bay-Nielsen M, Klarskov B, Bech K, et al. Levobupivacaine vs bupivacaine as infiltration anaesthesia in inguinal herniorrhaphy. Br J Anaesth. Feb. 1999;82(2):280-2. [pmid: 10365010].
45 Beddy P, Ridgway PF, Geoghegan T, et al. Inguinal hernia repair protects testicular function: a prospective study of open and laparoscopic herniorraphy. J Am Coll Surg. Jul. 2006;203(1):17-23. [pmid: 16798483].
46 Beets GL, Oosterhuis KJ, Go PM, et al. Longterm followup (12-15 years) of a randomized controlled trial comparing Bassini-Stetten, Shouldice, and high ligation with narrowing of the internal ring for primary inguinal hernia repair. J Am Coll Surg. Oct. 1997;185(4):352-7. [pmid: 9328383].
47 Bell RC, Price JG. Laparoscopic inguinal hernia repair using an anatomically contoured three-dimensional mesh. Surg Endosc. Nov. 2003;17(11):1784-8. [pmid: 12958677].
48 Bemdsen F, Sevonius D. Changing the path of inguinal hernia surgery decreased the recurrence rate ten-fold. Report from a county hospital. Eur J Surg. 2002;168(11):592-6. [pmid: 12699094].
49 Bencini L, Sanchez LJ. Learning curve for laparoscopic ventral hernia repair. Am J Surg. Mar. 2004;187(3):378-82. [pmid: 15006566].
50 Ben-David B, Katz E, Gaitini L, et al. Comparison of i.m. and local infiltration of ketorolac with and without local anaesthetic. Br J Anaesth. Oct. 1995;75(4):409-12. [pmid: 7488478].
51 Ben-Haim M, Kuriansky J, Tal R, et al. Pitfalls and complications with laparoscopic intraperitoneal expanded polytetrafluoroethylene patch repair of postoperative ventral hernia. Surg Endosc. May. 2002;16(5):785-8. [pmid: 11997822].
52 Benizri EI, Rahili A, Avallone S, et al. Open inguinal hernia repair by plug and patch: the value of fibrin sealant fixation. Hernia. Oct. 2006;10(5):389-94. [pmid: 16855852].
53 Berndsen F, Arvidsson D, Enander LK, et al. Postoperative convalescence after inguinal hernia surgery: prospective randomized multicenter study of laparoscopic versus shouldice inguinal hernia repair in 1042 patients. Hernia. Jul. 2002;6(2):56-61. [pmid: 12152639].
54 Berndsen F, Sevonius D. Changing the path of inguinal hernia surgery decreased the recurrence rate ten-fold. Report from a county hospital. Eur J Surg. 2002;168(11):592-6. [pmid: 12699094].
55 Berndsen FH, Petersson U, Arvidsson D, et al. Discomfort five years after laparoscopic and Shouldice inguinal hernia repair: a randomised trial with 867 patients. A report from the SMIL study group. Hernia. Aug. 2007;11(4):307-13. [pmid: 17440795].
56 Bessell JR, Baxter P, Riddell P, et al. A randomized controlled trial of laparoscopic extraperitoneal hernia repair as a day surgical procedure. Surg Endosc. May. 1996;10(5):495-500. [pmid: 8658325].
57 Bhattacharya P, Mandal MC, Mukhopadhyay S, et al. Unilateral paravertebral block: an alternative to conventional spinal anaesthesia for inguinal hernia repair. Acta Anaesthesiol Scand. Feb. 2010;54(2):246-51. [pmid: 19839949].
58 Biemans JM, Schmitz RF, Pierik EG, et al. Patient satisfaction after laparoscopic and conventional day case inguinal hernia repair. Ambul Surg. Mar. 1998;6(1):39-42.
59 Bilgin B, Ozmen MM, Zulfikaroglu B, et al. Totally extraperitoneal (TEP) hernia repair preperitoneal open repair (PPOR). Surg Endosc. 1997;11:542.
60 Billingham MJ, Basterfield SJ. Pediatric surgical technique: laparoscopic or open approach? A systematic review and meta-analysis. Eur J Pediatr Surg. Mar. 2010;20(2):73-7. [pmid: 19882502].
61 Birk D, Formentini A, Poch B, et al. The value of intraoperative laparoscopic examination of the contralateral inguinal ring during hernia repair in children. J Laparoendosc Adv Surg Tech A. Dec. 1998;8(6):373-9. [pmid: 9916590].
62 Bisgaard T, Bay-Nielsen M, Kehlet H. Groin hernia repair in young males: mesh or sutured repair?. Hernia. Oct. 2010;14(5):467-9. [pmid: 20454990].
63 Bittner R, Sauerland S, Schmedt CG. Comparison of endoscopic techniques vs Shouldice and other open nonmesh techniques for inguinal hernia repair: a meta-analysis of randomized controlled trials. Surg Endosc. May. 2005;19(5):605-15. [pmid: 15789255].
64 Bittner R, Gmahle E, Gmahle B, et al. Lightweight mesh and noninvasive fixation: an effective concept for prevention of chronic pain with laparoscopic hernia repair (TAPP). Surg Endosc. Dec. 2010;24(12):2958-64. [pmid: 20526620].
65 Blaser A. Use of fibrin glue in laparoscopic preperitoneal mesh hernioplasty. Surg Endosc. Mar. 2011;25:S153.
66 Borenstein SH, To T, Wajja A, et al. Effect of subspecialty training and volume on outcome after pediatric inguinal hernia repair. J Pediatr Surg. Jan. 2005;40(1):75-80. [pmid: 15868562].
67 Bozuk M, Schuster R, Stewart D, et al. Disability and chronic pain after open mesh and laparoscopic inguinal hernia repair. Am Surg. Oct. 2003;69(10):839-41. [pmid: 14570359].
68 Brandt ML. Pediatric hernias. Surg Clin North Am. Feb. 2008;88(1):27-43. vii. viii. [pmid: 18267160].
69 Bright E, Reddy VM, Wallace D, et al. The incidence and success of treatment for severe chronic groin pain after open, transabdominal preperitoneal, and totally extraperitoneal hernia repair. World J Surg. Apr. 2010;34(4):692-6. [pmid: 20130871].
70 Bringman S, Ek A, Haglind E, et al. Is a dissection balloon beneficial in bilateral, totally extraperitoneal, endoscopic hernioplasty? A randomized, prospective, multicenter study. Surg Laparosc Endosc Percutan Tech. Oct. 2001;11(5):322-6. [pmid: 11668230].
71 Bringman S, Ek A, Haglind E, et al. Is a dissection balloon beneficial in totally extraperitoneal endoscopic hernioplasty (TEP)? A randomized prospective multicenter study. Surg Endosc. Mar. 2001;15(3):266-70. [pmid: 11344426].
72 Brooks DC. A prospective comparison of laparoscopic and tension-free open herniorrhaphy. Arch Surg. Apr. 1994;129(4):361-6. [pmid: 8154962].
73 Brunner W, Schirnhofer J, Frass R, et al. Are recurrent groin hernia eligible for transumbilical laparoscopic single access repair?. Surg Endosc. Mar. 2011;25:S6.
74 Burney RE, Prabhu MA, Greenfield ML, et al. Comparison of spinal vs general anesthesia via laryngeal mask airway in inguinal hernia repair. Arch Surg. Feb. 2004;139(2):183-7. [pmid: 14769578].
75 Cahill J, Northeast AD, Jarret PE, et al. Sutures for inguinal herniorrhaphy--a comparison of monofilaments with PTFE. Ann R Coll Surg Engl. Mar. 1989;71(2):128-30. [pmid: 2705719].
76 Callesen T, Bech K, Thorup J, et al. Cryoanalgesia: effect on postherniorrhaphy pain. Anesth Analg. Oct. 1998;87(4):896-9. [pmid: 9768790].
77 Callesen T, Bech K, Nielsen R, et al. Pain after groin hernia repair. Br J Surg. Oct. 1998;85(10):1412-4. [pmid: 9782027].
78 Callesen T, Bech K, Andersen J, et al. Pain after primary inguinal herniorrhaphy: influence of surgical technique. J Am Coll Surg. Apr. 1999;188(4):355-9. [pmid: 10195718].
79 Callesen T, Bech K, Kehlet H. Prospective study of chronic pain after groin hernia repair. Br J Surg. Dec. 1999;86(12):1528-31. [pmid: 10594500].
80 Caliskan K, Nursal TZ, Caliskan E, et al. A method for the reduction of chronic pain after tension-free repair of inguinal hernia: iliohypogastric neurectomy and subcutaneous transposition of the spermatic cord. Hernia. Feb. 2010;14(1):51-5. [pmid: 19826895].
81 Campanelli G, Champault G, Pascual MH, et al. Randomized, controlled, blinded trial of Tissucol/Tisseel for mesh fixation in patients undergoing Lichtenstein technique for primary inguinal hernia repair: rationale and study design of the TIMELI trial. Hernia. Apr. 2008;12(2):159-65. [pmid: 18095052].
82 Canonico S. The use of human fibrin glue in the surgical operations. Acta Biomed Ateneo Parmense. Suppl 2. 2003;74:21-5. [pmid: 15055028].
83 Casati A, Moizo E, Marchetti C, et al. A prospective, randomized, double-blind comparison of unilateral spinal anesthesia with hyperbaric bupivacaine, ropivacaine, or levobupivacaine for inguinal herniorrhaphy. Anesth Analg. Nov. 2004;99(5):1387-92. [pmid: 15502035].
84 Castoro C, Polo P, Pignataro M, et al. Hernia study: Shouldice vs Lichtenstein technique on inguinal hernia repair: preliminary results of a mutlicentric randomized prospective trial. Br J Surg. 1996;83(Suppl 2):72. [pmid: 8653371].
85 Ceccarelli G, Casciola L, Pisanelli MC, et al. Comparing fibrin sealant with staples for mesh fixation in laparoscopic transabdominal hernia repair: a case control-study. Surg Endosc. Mar. 2008;22(3):668-73. [pmid: 17623245].
86 Celdran A, Frieyro O, de la Pinta JC, et al. The role of antibiotic prophylaxis on wound infection after mesh hernia repair under local anesthesia on an ambulatory basis. Hernia. Feb. 2004;8(1):20-2. [pmid: 14505238].
87 Cesana G, Olmi S, Croce E. Trans-abdominal pre-peritoneal laparoscopic inguinal hernia repair versus classical inguinotomic repair: A randomized study. Surg Endosc. Mar. 2011;25:S7.
88 Champault G, Bernard C, Rizk N, et al. Inguinal hernia repair: the choice of prosthesis outweighs that of technique. Hernia. Apr. 2007;11(2):125-8. [pmid: 17216121].
89 Champault G, Torcivia A, Paolino L, et al. A self-adhering mesh for inguinal hernia repair: preliminary results of a prospective, multicenter study. Hernia. 2011. Jul. 12. [pmid: 21748483].
90 Chan KL, Tam PK. Technical refinements in laparoscopic repair of childhood inguinal hernias. Surg Endosc. Jun. 2004;18(6):957-60. [pmid: 15095082].
91 Chan KY, Rohaizak M, Sukumar N, et al. Inguinal hernia repair by surgical trainees at a Malaysian teaching hospital. Asian J Surg. Oct. 2004;27(4):306-12. [pmid: 15564185].
92 Chan G, Chan CK. The characteristics of inguinal hernia recurrence in the modern era and the long-term outcomes after re-operation. Hernia. 2011. Jan. 26. [pmid: 21267616].
93 Chawla S, Lal P, Ganguly PK, et al. Endoscope-assisted inguinal hernia repair. J Soc Laparoendosc Surg. Jan-Mar. 2005;9(1):42-6. [pmid: 15791969].
94 Cheek CM, Black NA, Devlin HB, et al. Groin hernia surgery: a systematic review. Ann R Coll Surg Engl. Suppl 1. 1998;80:S1-80. [pmid: 11432408].
95 Chowbey PK, Bandyopadhyay SK, Sharma A, et al. Recurrent hernia following endoscopic total extraperitoneal repair. J Laparoendosc Adv Surg Tech A. Feb. 2003;13(1):21-5. [pmid: 12676017].
96 Chu CC, Chou CY, Hsu TM, et al. Intraoperative laparoscopy in unilateral hernia repair to detect a contralateral patent processus vaginalis. Pediatr Surg Int. 1993;8:385-89.
97 Chung RS, Rowland DY. Meta-analyses of randomized controlled trials of laparoscopic vs conventional inguinal hernia repairs. Surg Endosc. Jul. 1999;13(7):689-94. [pmid: 10384076].
98 Cingi A, Manukyan MN, Gulluoglu BM, et al. Use of resterilized polypropylene mesh in inguinal hernia repair: a prospective, randomized study. J Am Coll Surg. Dec. 2005;201(6):834-40. [pmid: 16310685].
99 Cocks JR. Laparoscopic inguinal hernioplasty: a comparison between transperitoneal and extraperitoneal techniques. Aust N Z J Surg. Jul. 1998;68(7):506-9. [pmid: 9669365].
100 Cohen RV, Alvarez G, Roll S, et al. Transabdominal or totally extraperitoneal laparoscopic hernia repair. Surg Laparosc Endosc. Aug. 1998;8(4):264-8. [pmid: 9703597].
101 Cohen RV, Morrel AC, Mendes JM, et al. Laparoscopic extraperitoneal repair of inguinal hernias. Surg Laparosc Endosc. 1998;8(1):14-6. [pmid: 9488563].
102 EU Hernia Trialists Collaboration. Laparoscopic compared with open methods of groin hernia repair: systematic review of randomized controlled trials. Br J Surg. Jul. 2000;87(7):860-7. [pmid: 10931019].
103 Collage RD, Rosengart MR. Abdominal wall infections with in situ mesh. Surg Infect (Larchmt). Jun. 2010;11(3):311-8. [pmid: 20583867].
104 Connelly NR, Reuben SS, Albert M, et al. Use of preincisional ketorolac in hernia patients: intravenous versus surgical site. Reg Anesth. May-Jun. 1997;22(3):229-32. [pmid: 9168213].
105 Conroy JM, Othersen HB Jr, Dorman BH, et al. A comparison of wound instillation and caudal block for analgesia following pediatric inguinal herniorrhaphy. J Pediatr Surg. Apr. 1993;28(4):565-7. [pmid: 8483071].
106 Corbitt JD Jr. Laparoscopic herniorrhaphy. Surg Laparosc Endosc. Mar. 1991;1(1):23-5. [pmid: 1669372].
107 Cornell RB, Kerlakian GM. Early complications and outcomes of the current technique of transperitoneal laparoscopic herniorrhaphy and a comparison to the traditional open approach. Am J Surg. Sep. 1994;168(3):275-9. [pmid: 8080067].
108 Courtney CA, Duffy K, Serpell MG, et al. Outcome of patients with severe chronic pain following repair of groin hernia. Br J Surg. Oct. 2002;89(10):1310-4. [pmid: 12296903].
109 Cox TC, Pearl JP, Parreno D, et al. Fellowship training eliminates the learning curve for laparoscopic inguinal hernia repair. Surg Endosc. Mar. 2011;25:S216.
110 Craven PD, Badawi N, Henderson-Smart DJ, et al. Regional (spinal, epidural, caudal) versus general anaesthesia in preterm infants undergoing inguinal herniorrhaphy in early infancy. Cochrane Database of Systematic Reviews. [internet]. Hoboken (NJ). John Wiley & Sons, Ltd. 2003;(3). 2010 Jul 2. [Art. No.: CD003669]. Available:. [doi: 10.1002/14651858.CD003669]. [pmid: 12917979].
111 Cunningham J, Temple WJ, Mitchell P, et al. Cooperative hernia study. Pain in the postrepair patient. Ann Surg. Nov. 1996;224(5):598-602. [pmid: 8916874].
112 Czudek S, Skrovina M, Adamcik L. Laparoscopic treatment of inguinal hernia - TOM(transabdominal onlay mesh). Wideochir I Inne Tech Maloinwazyjne. 2009;4(1):16-9.
113 Dallas KB, Froylich D, Choi JJ, et al. Laparoscopic versus open inguinal hernia repair in octogenarians: a follow-up study. Surg Endosc. Mar. 2011;25:S321.
114 Damamme A, Samama G, D'Alche-Gutier MJ, et al. Medicoeconomic evaluation of inguinal hernia repair: shouldice repair vs laparoscopy. Ann Chir. 1998;52(1):11-6. [pmid: 9752402].
115 Daniel Smith C, Tiao G, Beebe T. Intraoperative events common to videoscopic preperitoneal mesh inguinal herniorrhaphy. Am J Surg. Oct. 1997;174(4):403-5. [pmid: 9337162].
116 Danielsson P, Isacson S, Hansen MV. Randomised study of Lichtenstein compared with Shouldice inguinal hernia repair by surgeons in training. Eur J Surg. Jan. 1999;165(1):49-53. [pmid: 10069634].
117 Dasari B, Grant L, Irwin T. Immediate and long-term outcomes of Lichtenstein and Kugel patch operations for inguinal hernia repair. Ulster Med J. May. 2009;78(2):115-8. [pmid: 19568448].
118 Davenport M. Laparoscopic surgery in children. Ann R Coll Surg Engl. Sep. 2003;85(5):324-30. [pmid: 14594537].
119 Davis PJ, Cohen IT, McGowan FX Jr, et al. Recovery characteristics of desflurane versus halothane for maintenance of anesthesia in pediatric ambulatory patients. Anesthesiology. Feb. 1994;80(2):298-302. [pmid: 8311312].
120 van Hanswijck de Jonge P, Lloyd A, Horsfall L, et al. The measurement of chronic pain and health-related quality of life following inguinal hernia repair: a review of the literature. Hernia. Dec. 2008;12(6):561-9. [pmid: 18716856].
121 de Sa Ribeiro FA, Padron F, Castro TD, et al. Inguinal hernia repair with local anesthesia in the outpatient. Rev Col Bras Cir. Dec. 2010;37(6):397-402. [pmid: 21340253].
122 de Vries Reilingh TS, van Goor H, Charbon JA, et al. Repair of giant midline abdominal wall hernias: “components separation technique” versus prosthetic repair: interim analysis of a randomized controlled trial. World J Surg. Apr. 2007;31(4):756-63. [pmid: 17372669].
123 Decker D, Lindemann C, Springer W, et al. Endoscopic vs conventional hernia repair from an immunologic point of view. Surg Endosc. Apr. 1999;13(4):335-9. [pmid: 10094742].
124 Dedemadi G, Sgourakis G, Radtke A, et al. Laparoscopic versus open mesh repair for recurrent inguinal hernia: a meta-analysis of outcomes. Am J Surg. Aug. 2010;200(2):291-7. [pmid: 20678621].
125 Demiraran Y, Ilce Z, Kocaman B, et al. Does tramadol wound infiltration offer an advantage over bupivacaine for postoperative analgesia in children following herniotomy. Paediatr Anaesth. Oct. 2006;16(10):1047-50. [pmid: 16972834].
126 Demirbas S, Ogun I, Akta O, et al. Hernia operations using laparoscopic hernioplasty on military personnel with a short hospitalization time. Mil Med. Oct. 2003;168(10):835-9. [pmid: 14620650].
127 DeTurris SV, Cacchione RN, Mungara A, et al. Laparoscopic herniorrhaphy: beyond the learning curve. J Am Coll Surg. Jan. 2002;194(1):65-73. [pmid: 11800341].
128 Deysine M, Grimson RC, Soroff HS. Inguinal herniorrhaphy. Reduced morbidity by service standardization. Arch Surg. May. 1991;126(5):628-30. [pmid: 2021347].
129 Deysine M. Inguinal herniorrhaphy: 25-year results of technical improvements leading to reduced morbidity in 4,029 patients. Hernia. Jun. 2006;10(3):207-12. [pmid: 16758149].
130 Di Filippo A, Natale V, Del Po F, et al. Skin temperature during sympathetic block: a clinical comparison of bupivacaine 0.5% and ropivacaine 0.5% or 0.75%. Anaesth Intensive Care. Jun. 2006;34(3):334-7. [pmid: 16802486].
131 Di Vita G, Milano S, Frazzetta M, et al. Tension-free hernia repair is associated with an increase in inflammatory response markers against the mesh. Am J Surg. Sep. 2000;180(3):203-7. [pmid: 11084130].
132 Di Vita G, Milano S, Patti R, et al. Cytokine modifications after tension-free hernioplasty or open conventional inguinal hernia repair. Am J Surg. Jun. 2001;181(6):487-91. [pmid: 11513771].
133 Di Vita G, D'Agostino P, Patti R, et al. Acute inflammatory response after inguinal and incisional hernia repair with implantation of polypropylene mesh of different size. Langenbecks Arch Surg. Jul. 2005;390(4):306-11. [pmid: 15690201].
134 Dick AC, Deans GT, Irwin ST. A prospective study of adult inguinal hernia repairs using absorbable sutures. J R Coll Surg Edinb. Oct. 1996;41(5):319-20. [pmid: 8908956].
135 Dickinson KJ, Thomas M, Fawole AS, et al. Predicting chronic post-operative pain following laparoscopic inguinal hernia repair. Hernia. 2008;12(6):597-601. [pmid: 18661098].
136 Dierking GW, Dahl JB, Kanstrup J, et al. Effect of pre- vs postoperative inguinal field block on postoperative pain after herniorrhaphy. Br J Anaesth. Apr. 1992;68(4):344-8. [pmid: 1642910].
137 Dilek ON, Yucel A, Akbulut G, et al. Are there adverse effects of herniorrhaphy techniques on testicular perfusion? Evaluation by color Doppler ultrasonography. Urol Int. 2005;75(2):167-9. [pmid: 16123572].
138 Dion YM. Laparoscopic inguinal herniorrhaphy: appraisal of a cohort study. Can J Surg. Jun. 1996;39(3):229-32. [pmid: 8640623].
139 Dorflinger T, Kiil J. Absorbable suture in hernia repair. Acta Chir Scand. 1984;150(1):41-3. [pmid: 6322489].
140 DuBois JJ, Jenkins JR, Egan JC. Transinguinal laparoscopic examination of the contralateral groin in pediatric herniorrhaphy. Surg Laparosc Endosc. 1997;7(5):384-7. [pmid: 9348617].
141 Dueholm S, Forrest M, Hjortso E, et al. Pain relief following herniotomy: a double-blind randomized comparison between naproxen and placebo. Acta Anaesthesiol Scand. Jul. 1989;33(5):391-4. [pmid: 2678876].
142 Duff M, Mofidi R, Nixon SJ. Routine laparoscopic repair of primary unilateral inguinal hernias--a viable alternative in the day surgery unit?. Surgeon. Aug. 2007;5(4):209-12. [pmid: 17849956].
143 Edelman DS, Misiakos EP, Moses K. Extraperitoneal laparoscopic hernia repair with local anesthesia. Surg Endosc. Sep. 2001;15(9):976-80. [pmid: 11443449].
144 Edelman DS. Laparoscopic herniorrhaphy with porcine small intestinal submucosa: a preliminary study. J Soc Laparoendosc Surg. Jul-Sep. 2002;6(3):203-5. [pmid: 12166756].
145 Edelman DS. Fibrin glue fixation of bioactive extracellular matrix mesh compared with soft prolene mesh for laparoscopic hernia repair. Surg Laparosc Endosc Percutan Tech. Dec. 2008;18(6):569-72. [pmid: 19098662].
146 Eker HH, Klitsie PJ, Langeveld HJ, et al. TEP inguinal hernia repair compared with lichtenstein (the level-trial): a randomised controlled trial. Surg Endosc. Mar. 2011;25:S4.
147 Eller Miranda M, Duarte Lanna JC. Videolaparoscopy of the contralateral internal inguinal ring via the hernia sac in children with unilateral inguinal hernia-initial experience in Brazil, with a meta-analysis. Pediatr Surg Int. Sep. 2002;18(5-6):463-9. [pmid: 12415382].
148 El-Radaideh KM, Al-Ghazo MA, Bani-Hani KE. Combined subfascial and subcutaneous bupivacaine instillation for inguinal hernia wounds. Asian J Surg. Oct. 2006;29(4):242-6. [pmid: 17098656].
149 Nicks BA, Askew K. Hernias. eMedicine. [database online]. Omaha (NE). eMedicine.com. 2010. Jan. 25. 2010 Jul 14. Available: http://emedicine.medscape.com/article/775630-overview.
150 Eno LM, Spigelman AD. An audit of open and laparoscopic inguinal hernia repair. J Qual Clin Pract. Jun-Sep. 2000;20(2-3):56-9. [pmid: 11057983].
151 Inguinal hernia: epidemiology. [database online]. San Mateo (CA). Epocrates, Inc. 2010. 2010 Jul 14. [1 p]. Available: https://online.epocrates.com/noFrame/showPage.do?method=diseases&MonographId=723&ActiveSectionId=23.
152 Erhan Y, Erhan E, Aydede H, et al. Chronic pain after Lichtenstein and preperitoneal (posterior) hernia repair. Can J Surg. Oct. 2008;51(5):383-7. [pmid: 18841221].
153 Erichsen CJ, Vibits H, Dahl JB, et al. Wound infiltration with ropivacaine and bupivacaine for pain after inguinal herniotomy. Acta Anaesthesiol Scand. Jan. 1995;39(1):67-70. [pmid: 7725886].
154 Erol A, Topal A, Arbag H, et al. Auditory function after spinal anaesthesia: the effect of differently designed spinal needles. Eur J Anaesthesiol. May. 2009;26(5):416-20. [pmid: 19521297].
155 Ersin S, Aydin U, Makay O, et al. Is testicular perfusion influenced during laparoscopic inguinal hernia surgery?. Surg Endosc. Apr. 2006;20(4):685-9. [pmid: 16523371].
156 EU Hernia Trialists Collaboration. Mesh compared with non-mesh methods of open groin hernia repair: systematic review of randomized controlled trials. Br J Surg. Jul. 2000;87(7):854-9. [pmid: 10931018].
157 EU Hernia Trialists Collaboration. Repair of groin hernia with synthetic mesh: meta-analysis of randomized controlled trials. Ann Surg. Mar. 2002;235(3):322-32. [pmid: 11882753].
158 Evans C, Pollock AV. The reduction of surgical wound infections by prophylactic parenteral cephaloridine. A controlled clinical trial. Br J Surg. Jun. 1973;60(6):434-7. [pmid: 4577070].
159 Evans DS. Hunterian lecture. Laparoscopic transabdominal pre-peritoneal (TAPP) repair of groin hernia: one surgeon's experience of a developing technique. Ann R Coll Surg Engl. Nov. 2002;84(6):393-8. [pmid: 12484578].
160 Fallas MJ, Phillips EH. Laparoscopic inguinal herniorrhaphy. Curr Opin Gen Surg. 1994:198-202. [pmid: 7583968].
161 Farooq O, Batool Z, Din AU, et al. Anterior tension - free repair versus posterior preperitoneal repair for recurrent hernia. J Coll Physicians Surg Pak. Aug. 2007;17(8):465-8. [pmid: 17785123].
162 Feliu X, Torres G, Vinas X, et al. Preperitoneal repair for recurrent inguinal hernia: laparoscopic and open approach. Hernia. May. 2004;8(2):113-6. [pmid: 14634841].
163 Feliu X, Jaurrieta E, Vinas X, et al. Recurrent inguinal hernia: a ten-year review. J Laparoendosc Adv Surg Tech A. Dec. 2004;14(6):362-7. [pmid: 15684783].
164 Felix EL, Michas CA, Gonzalez MH Jr. Laparoscopic hernioplasty. TAPP vs TEP. Surg Endosc. Sep. 1995;9(9):984-9. [pmid: 7482218].
165 Felix EL, Michas CA, McKnight RL. Laparoscopic repair of recurrent hernias. Surg Endosc. Feb. 1995;9(2):135-8. discussion 138-9. [pmid: 7597580].
166 Felix EL, Michas CA, Gonzalez MH Jr. Laparoscopic repair of recurrent hernia. Am J Surg. Nov. 1996;172(5):580-4. [pmid: 8942567].
167 Felix EL, Michas CA, Gonzalez MH Jr. Laparoscopic hernioplasty: why does it work?. Surg Endosc. Jan. 1997;11(1):36-41. [pmid: 8994986].
168 Felix EL, Harbertson N, Vartanian S. Laparoscopic hernioplasty: significant complications. Surg Endosc. Apr. 1999;13(4):328-31. [pmid: 10094740].
169 Fell D, Derrington MC, Taylor E, et al. Paediatric postoperative analgesia. A comparison between caudal block and wound infiltration of local anaesthetic. Anaesthesia. Feb. 1988;43(2):107-10. [pmid: 3354802].
170 Ferzli G, Shapiro K, Chaudry G, et al. Laparoscopic extraperitoneal approach to acutely incarcerated inguinal hernia. Surg Endosc. Feb. 2004;18(2):228-31. [pmid: 14639475].
171 Ferzli GS, Khoury GE. Treating recurrence after a totally extraperitoneal approach. Hernia. Aug. 2006;10(4):341-6. [pmid: 16819562].
172 Fielding GA. Laparoscopic inguinal hernia repair. Aust N Z J Surg. May. 1995;65(5):304-7. [pmid: 7741670].
173 Filipi CJ, Gaston-Johansson F, McBride PJ, et al. An assessment of pain and return to normal activity. Laparoscopic herniorrhaphy vs open tension-free Lichtenstein repair. Surg Endosc. Oct. 1996;10(10):983-6. [pmid: 8864090].
174 Fine AP. Laparoscopic repair of inguinal hernia using Surgisis mesh and fibrin sealant. JSLS. Oct-Dec. 2006;10(4):461-5. [pmid: 17575758].
175 Fischer S, Cassivi S, Paul A, et al. Evidence-based medicine and special aspects in bilateral inguinal hernia repair. Hernia. 1999;3(2):89-95.
176 Fischer S, Troidl H, MacLean AA, et al. Prospective double-blind randomised study of a new regimen of pre-emptive analgesia for inguinal hernia repair: evaluation of postoperative pain course. Eur J Surg. Jul. 2000;166(7):545-51. [pmid: 10965833].
177 Fitzgibbons RJ Jr, Camps J, Cornet DA, et al. Laparoscopic inguinal herniorrhaphy. Results of a multicenter trial. Ann Surg. Jan. 1995;221(1):3-13. [pmid: 7826159].
178 Fleming WR, Elliott TB, Jones RM, et al. Randomized clinical trial comparing totally extraperitoneal inguinal hernia repair with the Shouldice technique. Br J Surg. Sep. 2001;88(9):1183-8. [pmid: 11531864].
179 Forte A, D'Urso A, Palumbo P, et al. Inguinal hernioplasty: the gold standard of hernia repair. Hernia. Mar. 2003;7(1):35-8. [pmid: 12612796].
180 Friis E, Lindahl F. The tension-free hernioplasty in a randomized trial. Am J Surg. Oct. 1996;172(4):315-9. [pmid: 8873520].
181 Fuenfer MM, Pitts RM, Georgeson KE. Laparoscopic exploration of the contralateral groin in children: an improved technique. J Laparoendosc Surg. Mar. Suppl 1. 1996;6:S1-4. [pmid: 8832919].
182 Fujita F, Lahmann B, Otsuka K, et al. Quantification of pain and satisfaction following laparoscopic and open hernia repair. Arch Surg. Jun. 2004;139(6):596-600. discussion 600-2. [pmid: 15197084].
183 Gao M, Han J, Tian J, et al. Vypro II mesh for inguinal hernia repair: a meta analysis of randomized controlled trials. Ann Surg. May. 2010;251(5):838-42. [pmid: 20395861].
184 Garg P, Rajagopal M, Varghese V, et al. Laparoscopic total extraperitoneal inguinal hernia repair with nonfixation of the mesh for 1,692 hernias. Surg Endosc. Jun. 2009;23(6):1241-5. [pmid: 18813990].
185 Gholghesaei M, Langeveld HR, Veldkamp R, et al. Costs and quality of life after endoscopic repair of inguinal hernia vs open tension-free repair: a review. Surg Endosc. Jun. 2005;19(6):816-21. [pmid: 15880287].
186 Gianetta E, Cuneo S, Vitale B, et al. Anterior tension-free repair of recurrent inguinal hernia under local anesthesia: a 7-year experience in a teaching hospital. Ann Surg. Jan. 2000;231(1):132-6. [pmid: 10636113].
187 Gilbert AI, Young J, Graham MF, et al. Combined anterior and posterior inguinal hernia repair: intermediate recurrence rates with three groups of surgeons. Hernia. Aug. 2004;8(3):203-7. [pmid: 15185129].
188 Gilbert AI, Graham MF, Young J, et al. Closer to an ideal solution for inguinal hernia repair: comparison between general surgeons and hernia specialists. Hernia. Apr. 2006;10(2):162-8. [pmid: 16374572].
189 Gillion JF, Fagniez PL. Chronic pain and cutaneous sensory changes after inguinal hernia repair: comparison between open and laparoscopic techniques. Hernia. 1999;3:75-80.
190 Girao R. Lichtenstein versus Shouldice. [unpublished].
191 Go PM. Overview of randomized trials in laparoscopic inguinal hernia repair. Semin Laparosc Surg. Dec. 1998;5(4):238-41. [pmid: 9854132].
192 Godfrey PJ, Greenan J, Ranasinghe DD, et al. Ventilatory capacity after three methods of anaesthesia for inguinal hernia repair: a randomized controlled trial. Br J Surg. Aug. 1981;68(8):587-9. [pmid: 7023596].
193 Gokcora IH. Low inguinal groove incision for indirect inguinal hernias in girls: a preliminary report on an incisional proposal. J Am Coll Surg. Oct. 1996;183(4):384-6. [pmid: 8843268].
194 Golash V. Laparoscopic transabdominal preperitoneal (TAPP) approach for irreducible, incarcerated and acutely obstructed inguinal hernias. Surg Endosc. Mar. 2011;25:S17.
195 Gontarz W, Wolanski L, Leksowski K. A comparison of two “tension free” inguinal hernia repair methods - laparoscopic hernioplasty vs anterior mesh technique. [Abstract]. Br J Surg. 1998;85(Suppl 2):101. [pmid: 9462395].
196 Gonullu NN, Cubukcu A, Alponat A. Comparison of local and general anesthesia in tension-free (Lichtenstein) hernioplasty: a prospective randomized trial. Hernia. Mar. 2002;6(1):29-32. [pmid: 12090578].
197 Goodwin JS 2nd, Traverso LW. A prospective cost and outcome comparison of inguinal hernia repairs. Laparoscopic transabdominal preperitoneal versus open tension-free preperitoneal. Surg Endosc. Sep. 1995;9(9):981-3. [pmid: 7482217].
198 Gramke HF, Petry JJ, Durieux ME, et al. Sublingual piroxicam for postoperative analgesia: preoperative versus postoperative administration: a randomized, double-blind study. Anesth Analg. Mar. 2006;102(3):755-8. [pmid: 16492824].
199 Grant AM, EU Hernia Trialists Collaboration. Open mesh versus non-mesh repair of groin hernia: meta-analysis of randomised trials based on individual patient data [corrected]. Hernia. Sep. 2002;6(3):130-6. [pmid: 12209302].
200 Grant AM, EU Hernia Trialists Collaboration. Laparoscopic versus open groin hernia repair: meta-analysis of randomised trials based on individual patient data. Hernia. Mar. 2002;6(1):2-10. [pmid: 12090575].
201 Grossmann PA, Wolf SA, Hopkins JW, et al. The efficacy of laparoscopic examination of the internal inguinal ring in children. J Pediatr Surg. Feb. 1995;30(2):214-7. discussion 217-8. [pmid: 7738740].
202 Grunwaldt LJ, Schwaitzberg SD, Rattner DW, et al. Is laparoscopic inguinal hernia repair an operation of the past?. J Am Coll Surg. Apr. 2005;200(4):616-20. [pmid: 15804477].
203 Gultekin FA, Kurukahvecioglu O, Karamercan A, et al. A prospective comparison of local and spinal anesthesia for inguinal hernia repair. Hernia. Apr. 2007;11(2):153-6. [pmid: 17136309].
204 Gunes Y, Secen M, Ozcengiz D, et al. Comparison of caudal ropivacaine, ropivacaine plus ketamine and ropivacaine plus tramadol administration for postoperative analgesia in children. Paediatr Anaesth. Jul. 2004;14(7):557-63. [pmid: 15200652].
205 Gupta A, Axelsson K, Thorn SE, et al. Low-dose bupivacaine plus fentanyl for spinal anesthesia during ambulatory inguinal herniorrhaphy: a comparison between 6 mg and 7. 5 mg of bupivacaine. Acta Anaesthesiol Scand. Jan. 2003;47(1):13-9. [pmid: 12492791].
206 Gürleyik E, Gürleyik G, Cetinkaya F, et al. The inflammatory response to open tension-free inguinal hernioplasty versus conventional repairs. Am J Surg. Mar. 1998;175(3):179-82. [pmid: 9560115].
207 Gursoy MH, Gurel M, Koltuksuz U, et al. Intraoperative laparoscopy by a flexible scope: is it reliable in contralateral childhood hernias?. J Soc Laparoendosc Surg. Jul-Sep. 1997;1(3):225-6. [pmid: 9876675].
208 Guzman-Valdivia Gomez G. Mesh prosthesis versus triangular flap from the anterior sheath of the abdominal rectus muscle in primary inguinal hernia repair. J Invest Surg. Jan-Feb. 2003;16(1):45-50. [pmid: 12554339].
209 Hadzic A, Kerimoglu B, Loreio D, et al. Paravertebral blocks provide superior same-day recovery over general anesthesia for patients undergoing inguinal hernia repair. Anesth Analg. Apr. 2006;102(4):1076-81. [pmid: 16551902].
210 Hair A, Duffy K, McLean J, et al. Groin hernia repair in Scotland. Br J Surg. 2000;87(12):1722-6. [pmid: 11122192].
211 Haitian Z, Jian L, Qinghua L, et al. Totally extraperitoneal laparoscopic hernioplasty: the optimal surgical approach. Surg Laparosc Endosc Percutan Tech. Dec. 2009;19(6):501-5. [pmid: 20027096].
212 Hakeem A, Mandal S, Dube M, et al. Preservation versus elective neurectomy of the ilioinguinal nerve for open mesh inguinal hernia surgery. Cochrane Database of Systematic Reviews. [internet]. Hoboken (NJ). John Wiley & Sons, Ltd. 2010;(6). 2010 Jul 2. [Art. No.: CD008527]. Available:. [doi: 10.1002/14651858.CD008527].
213 Halm JA, Heisterkamp J, Boelhouwer RU, et al. Totally extraperitoneal repair for bilateral inguinal hernia: does mesh configuration matter?. Surg Endosc. Oct. 2005;19(10):1373-6. [pmid: 16228861].
214 Harjai MM, Nagpal BM, Singh P, et al. A prospective randomized controlled study of Lichtenstein's tension free versus modified Bassini repair in the management of groin hernias. Med J Armed Forces India. Jan. 2007;63(1):40-3.
215 Hatch DA, Trockman B. Laparoscopy via patent processus vaginalis to prevent unnecessary contralateral exploration in boys with unilateral inguinal hernia or hydrocele. [abstract # 37]. J Urol. 1994;151:237A.
216 Hawasli A, Thao U, Chapital A. Laparoscopic transabdominal preperitoneal inguinal hernia repair for recurrent inguinal hernia. Am Surg. Mar. 2002;68(3):303-7. discussion 307-8. [pmid: 11894858].
217 Hay JM, Boudet MJ, Fingerhut A, et al. Shouldice inguinal hernia repair in the male adult: the gold standard? A multicenter controlled trial in 1578 patients. Ann Surg. Dec. 1995;222(6):719-27. [pmid: 8526578].
218 Hernandez-Granados P, Ontanon M, Lasala M, et al. Tension-free hernioplasty in primary inguinal hernia. A series of 2054 cases. Hernia. 2000;4(3):141-3.
219 Hetzer FH, Hotz T, Steinke W, et al. Gold standard for inguinal hernia repair: Shouldice or Lichtenstein?. Hernia. 1999;3(3):117-20.
220 Hidalgo M, Castillo MJ, Eymar JL, et al. Lichtenstein inguinal hernioplasty: sutures versus glue. Hernia. Oct. 2005;9(3):242-4. [pmid: 15891811].
221 Hilgert RE, Dorner A, Wittkugel O. Comparison of polydioxanone (PDS) and polypropylene (Prolene) for Shouldice repair of primary inguinal hernias: a prospective randomised trial. Eur J Surg. Apr. 1999;165(4):333-8. [pmid: 10365834].
222 Himpens JM. Laparoscopic inguinal hernioplasty. Repair with a conventional vs a new self-expandable mesh. Surg Endosc. Jul-Aug. 1993;7(4):315-8. [pmid: 8351604].
223 Himpens J, Cadiere GB, Bruyns J. Laparoscopic inguinal hernia repair: new policies. Dig Surg. 1997;14(5):433-7.
224 Hindmarsh AC, Cheong E, Lewis MP, et al. Attendance at a pain clinic with severe chronic pain after open and laparoscopic inguinal hernia repairs. Br J Surg. Sep. 2003;90(9):1152-4. [pmid: 12945086].
225 Holcomb GW 3rd, Morgan WM 3rd, Brock JW 3rd. Laparoscopic evaluation for contralateral patent processus vaginalis: Part II. J Pediatr Surg. Aug. 1996;31(8):1170-3. [pmid: 8863258].
226 Hon SF, Poon CM, Leong HT, et al. Pre-emptive infiltration of Bupivacaine in laparoscopic total extraperitoneal hernioplasty: a randomized controlled trial. Hernia. Feb. 2009;13(1):53-6. [pmid: 18704618].
227 Hong JY, Won Han S, Kim WO, et al. Fentanyl sparing effects of combined ketorolac and acetaminophen for outpatient inguinal hernia repair in children. J Urol. Apr. 2010;183(4):1551-5. [pmid: 20172547].
228 Horgan LF, Shelton JC, O'Riordan DC, et al. Strengths and weaknesses of laparoscopic and open mesh inguinal hernia repair: a randomized controlled experimental study. Br J Surg. Oct. 1996;83(10):1463-7. [pmid: 8944474].
229 Horharin P, Wilasrusmee C, Cherudchayaporn K, et al. Comparative study of tailor-made mesh plug herniorrhaphy versus Lichtenstein herniorrhaphy versus Bassini operation: a prospective clinical trial. Asian J Surg. Apr. 2006;29(2):74-8. [pmid: 16644506].
230 Horstmann R, Hellwig M, Classen C, et al. Impact of polypropylene amount on functional outcome and quality of life after inguinal hernia repair by the TAPP procedure using pure, mixed, and titanium-coated meshes. World J Surg. Sep. 2006;30(9):1742-9. [pmid: 16902744].
231 Horton MD, Florence MG. Simplified preperitoneal Marlex hernia repair. Am J Surg. May. 1993;165(5):595-9. [pmid: 8488944].
232 Horzic M, Kopljar M, Cupurdija K, et al. Quality of life changes after inguinal hernia repair using anterior rectus sheath--a preliminary study. Coll Antropol. Jun. 2006;30(2):349-53. [pmid: 16848150].
233 Huang CS, Huang CC, Lien HH. Prolene hernia system compared with mesh plug technique: a prospective study of short- to mid-term outcomes in primary groin hernia repair. Hernia. May. 2005;9(2):167-71. [pmid: 15703858].
234 Hussein MK, Khoury GS, Taha AM. Laparoscopic inguinal hernia repair. Int Surg. Jul-Sep. 1998;83(3):253-6. [pmid: 9870786].
235 Ismail M, Garg P. Laparoscopic inguinal total extraperitoneal hernia repair under spinal anesthesia without mesh fixation in 1,220 hernia repairs. Hernia. Apr. 2009;13(2):115-9. [pmid: 19005613].
236 Jacobs DO. Mesh repair of inguinal hernias--redux. N Engl J Med. Apr. 29. 2004;350(18):1895-7. [pmid: 15107484].
237 Jain SK, Jayant M, Norbu C. The role of antibiotic prophylaxis in mesh repair of primary inguinal hernias using prolene hernia system: a randomized prospective double-blind control trial. Trop Doct. Apr. 2008;38(2):80-2. [pmid: 18453491].
238 Jain SK, Vindal A. Gelatin-resorcin-formalin (GRF) tissue glue as a novel technique for fixing prosthetic mesh in open hernia repair. Hernia. Jun. 2009;13(3):299-304. [pmid: 19225855].
239 Jani K. Prospective randomized study of internal oblique aponeurotic flap repair for tension-free reinforcement of the posterior inguinal wall: a new technique. Int Surg. Jul-Aug. 2005;90(3):155-9. [pmid: 16466005].
240 Jönsson B, Zethraeus N. Costs and benefits of laparoscopic surgery--a review of the literature. Eur J Surg Suppl. 2000;(585):48-56. [pmid: 10885558].
241 Janu PG, Sellers KD, Mangiante EC. Mesh inguinal herniorrhaphy: a ten-year review. Am Surg. Dec. 1997;63(12):1065-9. discussion 1069-7. [pmid: 9393254].
242 Janu PG, Sellers KD, Mangiante EC. Recurrent inguinal hernia: preferred operative approach. Am Surg. Jun. 1998;64(6):569-73. discussion 573-4. [pmid: 9619180].
243 Jarhult J, Hakanson C, Akerud L. Laparoscopic treatment of recurrent inguinal hernias: experience from 281 operations. Surg Laparosc Endosc Percutan Tech. Apr. 1999;9(2):115-8. [pmid: 11757537].
244 Jeans S, Williams GL, Stephenson BM. Migration after open mesh plug inguinal hernioplasty: a review of the literature. Am Surg. Mar. 2007;73(3):207-9. [pmid: 17375772].
245 Jenkins JT, O'Dwyer PJ. Inguinal hernias. BMJ. Feb. 2. 2008;336(7638):269-72. [pmid: 18244999].
246 Jenkinson C, Lawrence K, McWhinnie D, et al. Sensitivity to change of health status measures in a randomized controlled trial: comparison of the COOP charts and the SF-36. Qual Life Res. Feb. 1995;4(1):47-52. [pmid: 7711691].
247 Jess P, Schultz K, Bendtzen K, et al. Systemic inflammatory responses during laparoscopic and open inguinal hernia repair: a randomised prospective study. Eur J Surg. Jul. 2000;166(7):540-4. [pmid: 10965832].
248 Joshi W, Connelly NR, Dwyer M, et al. A comparison of two concentrations of bupivacaine and adrenaline with and without fentanyl in paediatric inguinal herniorrhaphy. Paediatr Anaesth. 1999;9(4):317-20. [pmid: 10411767].
249 Juang D, Garey CL, Ostlie DJ, et al. Contralateral inguinal hernia after negative laparoscopic evaluation: a rare but real phenomenon. J Laparoendosc Adv Surg Tech A. 2011. Nov. 2. [pmid: 22047142].
250 Juul P, Christensen K. Randomized clinical trial of laparoscopic versus open inguinal hernia repair. Br J Surg. Mar. 1999;86(3):316-9. [pmid: 10201770].
251 Kald A, Anderberg B, Carlsson P, et al. Surgical outcome and cost-minimisation-analyses of laparoscopic and open hernia repair: a randomised prospective trial with one year follow up. Eur J Surg. Jul. 1997;163(7):505-10. [pmid: 9248984].
252 Kald A, Anderberg B, Smedh K, et al. Transperitoneal or totally extraperitoneal approach in laparoscopic hernia repair: results of 491 consecutive herniorrhaphies. Surg Laparosc Endosc. Apr. 1997;7(2):86-9. [pmid: 9109232].
253 Kalman SH, Bengtsson M, Martensson J. Liver function and halothane-diethyl-ether azeotrope anaesthesia. Re-evaluation of an obsolete drug with special reference to early postoperative effects. Acta Anaesthesiol Scand. Jan. 1995;39(1):34-8. [pmid: 7725882].
254 Karakayali F, Karatas M, Ozcelik U, et al. Influence of synthetic mesh on ilioinguinal nerve motor conduction and chronic groin pain after inguinal herniorrhaphy: a prospective randomized clinical study. Int Surg. Nov-Dec. 2007;92(6):344-50. [pmid: 18402129].
255 Kark AE, Kurzer M, Waters KJ. Tension-free mesh hernia repair: review of 1098 cases using local anaesthesia in a day unit. Ann R Coll Surg Engl. Jul. 1995;77(4):299-304. [pmid: 7574324].
256 Karthikesalingam A, Markar SR, Holt PJ, et al. Meta-analysis of randomized controlled trials comparing laparoscopic with open mesh repair of recurrent inguinal hernia. Br J Surg. Jan. 2010;97(1):4-11. [pmid: 20013926].
257 Kaufman A, Ritchey ML, Black CT. Cost-effective endoscopic examination of the contralateral inguinal ring. Urology. Apr. 1996;47(4):566-8. [pmid: 8638370].
258 Kawji R, Feichter A, Fuchsjager N, et al. Postoperative pain and return to activity after five different types of inguinal herniorrhaphy. Hernia. 1999;3(1):31-5.
259 Kaynak B, Celik F, Guner A, et al. Moloney darn repair versus lichtenstein mesh hernioplasty for open inguinal hernia repair. Surg Today. 2007;37(11):958-60. [pmid: 17952525].
260 Khajanchee YS, Urbach DR, Swanstrom LL, et al. Outcomes of laparoscopic herniorrhaphy without fixation of mesh to the abdominal wall. Surg Endosc. Oct. 2001;15(10):1102-7. [pmid: 11727079].
261 Khajanchee YS, Kenyon TA, Hansen PD, et al. Economic evaluation of laparoscopic and open inguinal herniorrhaphies: the effect of cost-containment measures and internal hospital policy decisions on costs and charges. Hernia. Aug. 2004;8(3):196-202. [pmid: 15146352].
262 Khan LR, Kumar S, Nixon SJ. Early results for new lightweight mesh in laparoscopic totally extra-peritoneal inguinal hernia repair. Hernia. Aug. 2006;10(4):303-8. [pmid: 16767341].
263 Khan LR, Liong S, De Beaux AC, et al. Lightweight mesh improves functional outcome in laparoscopic totally extra-peritoneal inguinal hernia repair. Hernia. Feb. 2010;14(1):39-45. [pmid: 19756914].
264 Khoury N. A comparative study of laparoscopic extraperitoneal and transabdominal preperitoneal herniorrhaphy. J Laparoendosc Surg. Dec. 1995;5(6):349-55. [pmid: 8746985].
265 Kimura T, Wada H, Yoshida M, et al. Laparoscopic inguinal hernia repair using fine-caliber instruments and polyester mesh. Surg Laparosc Endosc. Aug. 1998;8(4):300-3. [pmid: 9703606].
266 Kingsley D, Vogt DM, Nelson MT, et al. Laparoscopic intraperitoneal onlay inguinal herniorrhaphy. Am J Surg. Dec. 1998;176(6):548-53. [pmid: 9926788].
267 Kingsnorth AN, Gray MR, Nott DM. Prospective randomized trial comparing the Shouldice technique and plication darn for inguinal hernia. Br J Surg. Oct. 1992;79(10):1068-70. [pmid: 1422722].
268 Kingsnorth AN. Inguinal hernia outcome studies and the house that Lichtenstein built. Hernia. Sep. 1999;3(3):109-11.
269 Kingsnorth A, Hyland M, Porter C, et al. Prefix plug-and-patch versus Lichtenstein patch in inguinal hernia: prospective randomized double-blind study of medium-term outcome. Hernia in the 21st century. Toronto. 2000:246.
270 Kingsnorth AN, Cummings CG, Bennett DH. Local anaesthesia in elective inguinal hernia repair: a randomised, double-blind study comparing the efficacy of levobupivacaine with racemic bupivacaine. Eur J Surg. 2002;168(7):391-6. [pmid: 12463428].
271 Kiruparan P, Pettit SH. Prospective audit of 200 patients undergoing laparoscopic inguinal hernia repair with follow-up from 1 to 4 years. J R Coll Surg Edinb. Feb. 1998;43(1):13-6. [pmid: 9560499].
272 Klein SM, Pietrobon R, Nielsen KC, et al. Paravertebral somatic nerve block compared with peripheral nerve blocks for outpatient inguinal herniorrhaphy. Reg Anesth Pain Med. Sep-Oct. 2002;27(5):476-80. [pmid: 12373694].
273 Klin B, Efrati Y, Abu-Kishk I, et al. The contribution of intraoperative transinguinal laparoscopic examination of the contralateral side to the repair of inguinal hernias in children. World J Pediatr. May. 2010;6(2):119-24. [pmid: 20490767].
274 Knapp RW, Mullen JT. Clinical evalation of the the of local anesthesia for repair of inguinal hernia. Am Surg. Dec. 1976;42(12):908-10. [pmid: 999082].
275 Knock MT, Weidema WF, Stassen LP, et al. Endoscopic totally extraperitoneal repair of bilateral inguinal hernias. Br J Surg. 1999;86(10):1312-6. [pmid: 10540140].
276 Kocijan R, Sandberg S, Chan YW, et al. Anatomical changes after inguinal hernia treatment: a reason for chronic pain and recurrent hernia. Surg Endosc. Feb. 2010;24(2):395-9. [pmid: 19551430].
277 Koinig H, Marhofer P, Krenn CG, et al. Analgesic effects of caudal and intramuscular S(+)-ketamine in children. Anesthesiology. Oct. 2000;93(4):976-80. [pmid: 11020749].
278 Koning GG, Koole D, de Jongh MA, et al. The transinguinal preperitoneal hernia correction vs Lichtenstein's technique; is TIPP top. Hernia. 2010. Nov. 9. [pmid: 21061139].
279 Korenstein D, McGinn T. EBM on call: management of minimally symptomatic inguinal hernia. Mt Sinai J Med. Jul-Aug. 2008;75(4):401-4. [pmid: 18729158].
280 Korman JE, Hiatt JR, Feldmar D, et al. Mesh configurations in laparoscopic extraperitoneal herniorrhaphy. A comparison of techniques. Surg Endosc. Nov. 1997;11(11):1102-5. [pmid: 9348384].
281 Koukourou A, Lyon W, Rice J, et al. Prospective randomized trial of polypropylene mesh compared with nylon darn in inguinal hernia repair. Br J Surg. Jul. 2001;88(7):931-4. [pmid: 11442522].
282 Kovacs JB, Gorog D, Szabo J, et al. Prospective randomized trial comparing Shouldice and Bassini-Kirschner operation technique in primary inguinal hernia repair. Acta Chir Hung. 1997;36(1-4):179-81. [pmid: 9408337].
283 Kozol R, Lange PM, Kosir M, et al. A prospective, randomized study of open vs laparoscopic inguinal hernia repair. An assessment of postoperative pain. Arch Surg. Mar. 1997;132(3):292-5. [pmid: 9125030].
284 Krahenbuhl L, Frei E. Laparoscopic inguinal hernia repair: an individualized approach?. Dig Surg. 1997;14(2):82-7.
285 Krähenbühl L, Schäfer M, Schilling M, et al. Simultaneous repair of bilateral groin hernias: open or laparoscopic approach?. Surg Laparosc Endosc. Aug. 1998;8(4):313-8. [pmid: 9703609].
286 Krane EJ, Haberkern CM, Jacobson LE. Postoperative apnea, bradycardia, and oxygen desaturation in formerly premature infants: prospective comparison of spinal and general anesthesia. Anesth Analg. Jan. 1995;80(1):7-13. [pmid: 7802303].
287 Krupinski R, Narebski J, Pomorski L, et al. Outpatient uncomplicated inguinal hernia repair versus in-hospital procedure - Analysis of 148 cases. Med Sci Monit. 1997;3(2):213-6.
288 Kucuk HF, Sikar HE, Kurt N, et al. Lichtenstein or darn procedure in inguinal hernia repair: a prospective randomized comparative study. Hernia. Aug. 2010;14(4):357-60. [pmid: 20461537].
289 Kuhry E, van Veen RN, Langeveld HR, et al. Open or endoscopic total extraperitoneal inguinal hernia repair? A systematic review. Surg Endosc. Feb. 2007;21(2):161-6. [pmid: 17171311].
290 Kumar S, Gupta RL, Chawla R. Efficacy and safety of promethazine hydrochloride as a local anaesthetic agent for inguinal hernia repair: a pilot study. Br J Clin Pract. Jan-Feb. 1997;51(1):33-5. [pmid: 9158269].
291 Kumar S, Wilson RG, Nixon SJ, et al. Chronic pain after laparoscopic and open mesh repair of groin hernia. Br J Surg. Nov. 2002;89(11):1476-9. [pmid: 12390395].
292 Kunz R, Schwarz A, Beger HG. Laparoscopic transperitoneal hernia repair vs. Shouldice herniorrhaphy - preliminary results of a prospectively randomized trial. Chirurgie Endoscopique. 1993. (Numero Hors Serie; no. 12).
293 Kux M, Fuchsjager N, Schemper M. Shouldice is superior to Bassini inguinal herniorrhaphy. Am J Surg. Jul. 1994;168(1):15-8. [pmid: 8024092].
294 Kuzu MA, Hazinedaroglu S, Dolalan S, et al. Prevention of surgical site infection after open prosthetic inguinal hernia repair: efficacy of parenteral versus oral prophylaxis with amoxicillin-clavulanic acid in a randomized clinical trial. World J Surg. Jun. 2005;29(6):794-9. [pmid: 15889218].
295 Lai HS, Wei CF. Miniincision for pediatric inguinal herniorraphy. Formosan J Surg. 1998;31(3):159-65.
296 Lange DH, Aufenacker TJ, Roest M, et al. Inguinal hernia surgery in The Netherlands: a baseline study before the introduction of the Dutch Guidelines. Hernia. May. 2005;9(2):172-7. [pmid: 15723152].
297 Lange JF. Operation compared with watchful waiting in elderly male inguinal hernia patients: A review and data analysis. J Am Coll Surg. 2011;212(2):251-259.e4. [pmid: 21183367].
298 Lau H, Lee F, Patil NG, et al. Early outcomes of laparoscopic totally extraperitoneal hernia repair versus open tension-free mesh hernioplasty. Asian J Surg. 2000;23(3):244-8.
299 Lau H, Lee F. Determinant factors of pain after ambulatory inguinal herniorrhaphy: a multi-variate analysis. Hernia. 2001;5(1):17-20. [pmid: 11387717].
300 Lau H, Wong C, Goh LC, et al. Prospective randomized trial of pre-emptive analgesics following ambulatory inguinal hernia repair: intravenous ketorolac versus diclofenac suppository. ANZ J Surg. Oct. 2002;72(10):704-7. [pmid: 12534378].
301 Lau H, Lee F. Lessons learned from ligation of indirect hernia sac: an alternative to reduction during endoscopic extraperitoneal inguinal hernioplasty. J Laparoendosc Adv Surg Tech A. Dec. 2002;12(6):419-23. [pmid: 12590722].
302 Lau H, Lee F. A prospective comparative study of needlescopic and conventional endoscopic extraperitoneal inguinal hernioplasty. Surg Endosc. Dec. 2002;16(12):1737-40. [pmid: 12085148].
303 Lau H, Patil NG, Yuen WK, et al. Prevalence and severity of chronic groin pain after endoscopic totally extraperitoneal inguinal hernioplasty. Surg Endosc. Oct. 2003;17(10):1620-3. [pmid: 12874688].
304 Lau H, Patil NG, Lee FC. Systematic review and meta-analysis of clinical trials comparing endoscopic totally extraperitoneal inguinal hernioplasty with open repair of inguinal hernia. Ann Coll Surg Hong Kong. Feb. 2003;7(1):2-10.
305 Lau H, Patil NG. A prospective comparison of ambulatory endoscopic totally extraperitoneal inguinal hernioplasty versus open mesh hernioplasty. Ambul Surg. Dec. 2003;10(3):137-41.
306 Lau H, Patil NG. Selective non-stapling of mesh during unilateral endoscopic total extraperitoneal inguinal hernioplasty: a case-control study. Arch Surg. Dec. 2003;138(12):1352-5. [pmid: 14662538].
307 Lau H, Patil NG, Yuen WK. Is endoscopic totally extraperitoneal hernioplasty justified for the repair of groin hernia in female patients?. Surg Endosc. Dec. 2005;19(12):1544-8. [pmid: 16308798].
308 Lauscher JC, Yafaei K, Buhr HJ, et al. Laparoscopic and open inguinal hernia repair with alloplastic material: do the subjective and objective parameters differ in the long-term course?. Surg Laparosc Endosc Percutan Tech. Oct. 2008;18(5):457-63. [pmid: 18936666].
309 Lauscher JC, Yafaei K, Buhr HJ, et al. Total extraperitoneal hernioplasty: does the long-term clinical course depend on the type of mesh?. J Laparoendosc Adv Surg Tech A. Dec. 2008;18(6):803-8. [pmid: 19105667].
310 Lawrence K, McWhinnie D, Goodwin A, et al. Randomised controlled trial of laparoscopic versus open repair of inguinal hernia: early results. BMJ. Oct. 14. 1995;311(7011):981-5. [pmid: 7580639].
311 Lawrence K, McWhinnie D, Goodwin A, et al. An economic evaluation of laparoscopic versus open inguinal hernia repair. J Public Health Med. Mar. 1996;18(1):41-8. [pmid: 8785074].
312 Lawrence K, McWhinnie D, Jenkinson C, et al. Quality of life in patients undergoing inguinal hernia repair. Ann R Coll Surg Engl. Jan. 1997;79(1):40-5. [pmid: 9038494].
313 Lazorthes F, Chiotasso P, Massip P, et al. Local antibiotic prophylaxis in inguinal hernia repair. Surg Gynecol Obstet. Dec. 1992;175(6):569-70. [pmid: 1448739].
314 Lee Y, Liang J. Experience with 450 cases of micro-laparoscopic herniotomy in infants and children. Pediatr Endosurg Innov Tech. 2002;6(1):25-8.
315 Lee SL, Sydorak RM, Lau ST. Laparoscopic contralateral groin exploration: is it cost effective?. J Pediatr Surg. Apr. 2010;45(4):793-5. [pmid: 20385289].
316 Leibl BJ, Daubler P, Schmedt CG, et al. Long-term results of a randomized clinical trial between laparoscopic hernioplasty and shouldice repair. Br J Surg. Jun. 2000;87(6):780-3. [pmid: 10848859].
317 Leibl BJ, Jäger C, Kraft B, et al. Laparoscopic hernia repair--TAPP or/and TEP?. Langenbecks Arch Surg. Apr. 2005;390(2):77-82. [pmid: 15711997].
318 Lepere M, Benchetrit S, Debaert M, et al. A multicentric comparison of transabdominal versus totally extraperitoneal laparoscopic hernia repair using PARIETEX meshes. JSLS. Apr-Jun. 2000;4(2):147-53. [pmid: 10917122].
319 Lepere M, Benchetrit S, Bertrand JC, et al. Laparoscopic resorbable mesh fixation. Assessment of an innovative disposable instrument delivering resorbable fixation devices: I-Clip(TM). Final results of a prospective multicentre clinical trial. Hernia. Apr. 2008;12(2):177-83. [pmid: 18085347].
320 Lerut J, Foxius A, Collard A. Evaluation criteria of inguinal hernia repair. Acta Chir Belg. Jun. 1998;98(3):127-31. [pmid: 9689973].
321 Leibl BJ, Schmedt CG, Ulrich M, et al. Laparoscopic hernia repair -- the facts, but no fashion. Langenbecks Arch Surg. Jun. 1999;384(3):302-11. [pmid: 10437621].
322 Lin LC, Sun YC, Tseng KF, et al. Comparison of preoperative and postoperative iliohypogastric ilioinguinal nerve block for pediatric herniorrhaphy patients. Ma Zui Xue Za Zhi. Jun. 1993;31(2):91-6. [pmid: 7934692].
323 Lin CF, Wong KL, Chan YL, et al. Comparison of local infiltration of tenoxicam and intravenous tenoxicam for postoperative analgesia in herniorrhaphy. Acta Anaesthesiol Sin. Mar. 1998;36(1):23-9. [pmid: 9807846].
324 Lin CD, Tsai YC, Chang SJ, et al. Surgical outcomes of mini laparoscopic herniorrhaphy in infants. J Urol. Mar. 2011;185(3):1071-6. [pmid: 21256513].
325 Litwin D, Rossi L, Oleniuk F, et al. Laparoscopic groin hernia repair. Int Surg. Oct-Dec. 1994;79(4):296-9. [pmid: 7713694].
326 Liu YC, Kang HM, Liou CM, et al. Comparison of antiemetic effect among ephedrine, droperidol and metoclopramide in pediatric inguinal hernioplasty. Ma Zui Xue Za Zhi. Mar. 1992;30(1):37-41. [pmid: 1608318].
327 Liu C, Chin T, Jan SE, et al. Intraoperative laparoscopic diagnosis of contralateral patent processus vaginalis in children with unilateral inguinal hernia. Br J Surg. Jan. 1995;82:106-8. [pmid: 7881924].
328 Ljem MS, Halsema JA, Van Graaft YD, et al. Cost-effectiveness of extraperitoneal laparoscopic inguinal hernia repair: a randomized comparison with conventional herniorrhaphy. Ann Surg. 1997;226(6):668-76. [pmid: 9409566].
329 Lobe TE, Schropp KP. Inguinal hernias in pediatrics: initial experience with laparoscopic inguinal exploration of the asymptomatic contralateral side. J Laparoendosc Surg. Jun. 1992;2(3):135-40. discussion 141. [pmid: 1535806].
330 Lorenz D, Stark E, Oestreich K, et al. Laparoscopic hernioplasty versus conventional hernioplasty (Shouldice): results of a prospective randomized trial. World J Surg. Jun. 2000;24(6):739-45. discussion 745-6. [pmid: 10773129].
331 Lotan G, Efrati Y, Stolero S, et al. Transinguinal laparoscopic examination: an end to the controversy on repair of inguinal hernia in children. Isr Med Assoc J. Jun. 2004;6(6):339-41. [pmid: 15214460].
332 Lowham AS, Filipi CJ, Fitzgibbons RJ Jr, et al. Mechanisms of hernia recurrence after preperitoneal mesh repair: traditional and laparoscopic. Ann Surg. 1997;225(4):422-31. [pmid: 9114802].
333 Lugo Vicente HL. The pediatric inguinal hernia: is contralateral exploration justified. Bol Asoc Med P R. Jan-Feb. 1995;87(1-2):8-11. [pmid: 7786359].
334 Lukaszczyk JJ, Preletz RJ, Morrow GJ, et al. Laparoscopic herniorrhaphy versus traditional open repair at a community hospital. J Laparoendosc Surg. Aug. 1996;6(4):203-8. [pmid: 8877736].
335 Machotta A, Risse A, Bercker S, et al. Comparison between instillation of bupivacaine versus caudal analgesia for postoperative analgesia following inguinal herniotomy in children. Paediatr Anaesth. Jun. 2003;13(5):397-402. [pmid: 12791112].
336 Madden GJ, Devitt P, Malycha P, et al. Laparoscopic versus open inguinal hernia repair. Br J Surg. 1993;80(Suppl):38-9.
337 Maddern GJ, Rudkin G, Bessell JR, et al. A comparison of laparoscopic and open hernia repair as a day surgical procedure. Surg Endosc. Dec. 1994;8(12):1404-8. [pmid: 7878506].
338 Maddox MM, Smith DP. A long-term prospective analysis of pediatric unilateral inguinal hernias: should laparoscopy or anything else influence the management of the contralateral side?. J Pediatr Urol. Apr. 2008;4(2):141-5. [pmid: 18631911].
339 Maggiore D, Muller G, Hafanaki J. Bassini vs Lichtenstein: two basic techniques for inguinal hernia treatment. Hernia. 2001;5(1):21-4. [pmid: 11387718].
340 Mahon D, Decadt B, Rhodes M. Prospective randomized trial of laparoscopic (transabdominal preperitoneal) vs open (mesh) repair for bilateral and recurrent inguinal hernia. Surg Endosc. Sep. 2003;17(9):1386-90. [pmid: 12802653].
341 Malviya S, Fear DW, Roy WL, et al. Adequacy of caudal analgesia in children after penoscrotal and inguinal surgery using 0.5 or 1.0 ml.kg-1 bupivacaine 0.125%. Can J Anaesth. May. 1992;39(5 Pt 1):449-53. [pmid: 1596968].
342 Mann DV, Prout J, Havranek E, et al. Late-onset deep prosthetic infection following mesh repair of inguinal hernia. Am J Surg. Jul. 1998;176(1):12-4. [pmid: 9683124].
343 Mann DV, Havranek E, Chan YC, et al. Simultaneous mesh repair of bilateral groin hernia: a comparison of laparoscopic and open techniques. Minim Invasive Ther Allied Technol. Jul. 1998;7(2):181-5.
344 Marappan S, Veitch PS, Barrie WW, et al. Laparoscopic hernia repair in Leicester General Hospital: a prospective audit of 94 patients. Ann R Coll Surg Engl. Jul. 1996;78(4):359-62. [pmid: 8712651].
345 Markar SR, Karthikesalingam A, Alam F, et al. Partially or completely absorbable versus nonabsorbable mesh repair for inguinal hernia: a systematic review and meta-analysis. Surg Laparosc Endosc Percutan Tech. Aug. 2010;20(4):213-9. [pmid: 20729687].
346 Markey JR, Montiague R, Winnie AP. A comparative efficacy study of hyperbaric 5% lidocaine and 1.5% lidocaine for spinal anesthesia. Anesth Analg. Nov. 1997;85(5):1105-7. [pmid: 9356108].
347 Massaron S, Bona S, Fumagalli U, et al. Analysis of post-surgical pain after inguinal hernia repair: a prospective study of 1,440 operations. Hernia. Dec. 2007;11(6):517-25. [pmid: 17646895].
348 Massaron S, Bona S, Fumagalli U, et al. Long-term sequelae after 1,311 primary inguinal hernia repairs. Hernia. Feb. 2008;12(1):57-63. [pmid: 17851727].
349 Matsota P, Papageorgiou-Brousta M, Kostopanagiotou G. Wound infiltration with levobupivacaine: an alternative method of postoperative pain relief after inguinal hernia repair in children. Eur J Pediatr Surg. Aug. 2007;17(4):270-4. [pmid: 17806025].
350 Matyja A, Kibil W, Pach R, et al. Assessment of inguinal hernia treatment results in patients operated on with mesh using Lichtenstein, PHS and Robbins-Rutkow techniques. Wideochir I Inne Tech Maloinwazyjne. 2010;5(1):27-34.
351 Mayagoitia JC. Inguinal hernioplasty with the Prolene Hernia System. Hernia. Feb. 2004;8(1):64-6. [pmid: 14618421].
352 Mayagoitia JC, Prieto-Diaz Chavez E, Suarez D, et al. Predictive factors comparison of complications and recurrences in three tension-free herniorraphy techniques. Hernia. Apr. 2006;10(2):147-51. [pmid: 16453076].
353 McCormack K, Wake BL, Fraser C, et al. Transabdominal pre-peritoneal (TAPP) versus totally extraperitoneal (TEP) laparoscopic techniques for inguinal hernia repair: a systematic review. Hernia. May. 2005;9(2):109-14. [pmid: 15703862].
354 McCormack K, Wake B, Perez J, et al. Laparoscopic surgery for inguinal hernia repair: systematic review of effectiveness and economic evaluation. Health Technol Assess. Apr. 2005;9(14):1-203. [pmid: 15842951].
355 McCormack K, Scott N, Go PM, et al. Laparoscopic techniques versus open techniques for inguinal hernia repair. Cochrane Database of Systematic Reviews. [internet]. Hoboken (NJ). John Wiley & Sons, Ltd. 2003;(1). 2010 Jul 2. ]. [Art. No.: CD001785]. Available:. [doi: 10.1002/14651858.CD001785]. [pmid: 12535413].
356 McGillicuddy JE. Prospective randomized comparison of the Shouldice and Lichtenstein hernia repair procedures. Arch Surg. Sep. 1998;133(9):974-8. [pmid: 9749850].
357 McIntosh E, Donaldson C, Grant A. Economic evaluation of open versus laparoscopic hernia repair: some pragmatic considerations for the measurement of costs. Semin Laparosc Surg. Dec. 1998;5(4):242-7. [pmid: 9854133].
358 McIntosh A, Hutchinson A, Roberts A, et al. Evidence-based management of groin hernia in primary care--a systematic review. Fam Pract. Oct. 2000;17(5):442-7. [pmid: 11021907].
359 McNally MP, Byrd KA, Duncan JE, et al. Laparoscopic versus open inguinal hernia repair: Expeditionary Medical Facility Kuwait experience. Mil Med. Dec. 2009;174(12):1320-3. [pmid: 20055075].
360 Mellinger JD. Primary inguinal hernia repair: open or laparoscopic, that is the question. Point Surg Endosc. Jul. 2004;18(7):1144-8. [pmid: 15156373].
361 Memon MA, Feliu X, Sallent EF, et al. Laparoscopic repair of recurrent hernias. Surg Endosc. Aug. 1999;13(8):807-10. [pmid: 10430691].
362 Memon MA, Cooper NJ, Memon B, et al. Meta-analysis of randomized clinical trials comparing open and laparoscopic inguinal hernia repair. Br J Surg. Dec. 2003;90(12):1479-92. [pmid: 14648725].
363 Menakuru SR, Philip T, Ravindranath N, et al. Outcome of inguinal hernia repair at two rural hospitals in northern Scotland. Surgeon. Dec. 2006;4(6):343-5. [pmid: 17152198].
364 Merello J, Guerra GA, Madriz J, et al. Laparoscopic TEP versus open Lichtenstein hernia repair: randomized trial. Surg Endosc. 1997;11:545.
365 Merhav H, Rothstein H, Eliraz A, et al. A comparison of pulmonary functions and oxygenation following local, spinal or general anaesthesia in patients undergoing inguinal hernia repair. Int Surg. Jul-Sep. 1993;78(3):257-61. [pmid: 8276554].
366 Metzger J, Lutz N, Laidlaw I. Guidelines for inguinal hernia repair in everyday practice. Ann R Coll Surg Engl. May. 2001;83(3):209-14. [pmid: 11432143].
367 Miedema BW, Ibrahim SM, Davis BD, et al. A prospective trial of primary inguinal hernia repair by surgical trainees. Hernia. Feb. 2004;8(1):28-32. [pmid: 12898290].
368 Miguel PR, Reusch M, da Rosa AL, et al. Laparoscopic hernia repair--complications. J Soc Laparoendosc Surg. Jan-Mar. 1998;2(1):35-40. [pmid: 9876708].
369 Mikkelsen SS, Knudsen KE, Kristensen BB, et al. Comparison of tenoxicam by intramuscular injection or wound infiltration for analgesia after inguinal herniorrhaphy. Anesth Analg. Dec. 1996;83(6):1239-43. [pmid: 8942593].
370 Millikan KW, Kosik ML, Doolas A. A prospective comparison of transabdominal preperitoneal laparoscopic hernia repair versus traditional open hernia repair in a university setting. Surg Laparosc Endosc. Aug. 1994;4(4):247-53. [pmid: 7952432].
371 Miltenburg DM, Nuchtern JG, Jaksic T, et al. Laparoscopic evaluation of the pediatric inguinal hernia--a meta-analysis. J Pediatr Surg. Jun. 1998;33(6):874-9. [pmid: 9660219].
372 Miyazaki K, Nakamura F, Narita Y, et al. Comparison of Bassini repair and mesh-plug repair for primary inguinal hernia: a retrospective study. Surg Today. 2001;31(7):610-4. [pmid: 11495156].
373 Mok KT, Wang BW, Chang HT, et al. Laparoscopic versus open preperitoneal prosthetic herniorrhaphy for recurrent inguinal hernia. Int Surg. Apr-Jun. 1998;83(2):174-6. [pmid: 9851340].
374 Mokete M, Earnshaw JJ. Evolution of an inguinal hernia surgery practice. Postgrad Med J. Mar. 2001;77(905):188-90. [pmid: 11222828].
375 Mollen KP, Kane TD. Inguinal hernia: what we have learned from laparoscopic evaluation of the contralateral side. Curr Opin Pediatr. Jun. 2007;19(3):344-8. [pmid: 17505198].
376 Montupet P, Esposito C. Fifteen years experience in laparoscopic inguinal hernia repair in pediatric patients. Results and considerations on a debated procedure. Surg Endosc. Feb. 2011;25(2):450-3. [pmid: 20585959].
377 Moores MA, Wandless JG, Fell D. Paediatric postoperative analgesia. A comparison of rectal diclofenac with caudal bupivacaine after inguinal herniotomy. Anaesthesia. Feb. 1990;45(2):156-8. [pmid: 2321721].
378 Morgan M, Reynolds A, Swan AV, et al. Are current techniques of inguinal hernia repair optimal? A survey in the United Kingdom. Ann R Coll Surg Engl. 1991;73(6):341-5. [pmid: 1759760].
379 Muller-Riemenschneider F, Roll S, Friedrich M, et al. Medical effectiveness and safety of conventional compared to laparoscopic incisional hernia repair: a systematic review. Surg Endosc. Dec. 2007;21(12):2127-36. [pmid: 17763905].
380 Mulroy MF, Greengrass R, Ganapathy S, et al. Sameridine is safe and effective for spinal anesthesia: a comparative dose-ranging study with lidocaine for inguinal hernia repair. Anesth Analg. Apr. 1999;88(4):815-21. [pmid: 10195530].
381 Murat I, Baujard C, Foussat C, et al. Tolerance and analgesic efficacy of a new i.v. paracetamol solution in children after inguinal hernia repair. Paediatr Anaesth. Aug. 2005;15(8):663-70. [pmid: 16029401].
382 Muzio G, Bernard K, Polliand C, et al. Impact of peritoneal tears on the outcome and late results (4 years) of endoscopic totally extra-peritoneal inguinal hernioplasty. Hernia. Oct. 2006;10(5):426-9. [pmid: 16932845].
383 Naguib M, Sharif AM, Seraj M, et al. Ketamine for caudal analgesia in children: comparison with caudal bupivacaine. Br J Anaesth. Nov. 1991;67(5):559-64. [pmid: 1751269].
384 Naguib M, el Gammal M, Elhattab YS, et al. Midazolam for caudal analgesia in children: comparison with caudal bupivacaine. Can J Anaesth. Sep. 1995;42(9):758-64. [pmid: 7497553].
385 Naja ZM, Raf M, El Rajab M, et al. Nerve stimulator-guided paravertebral blockade combined with sevoflurane sedation versus general anesthesia with systemic analgesia for postherniorrhaphy pain relief in children: a prospective randomized trial. Anesthesiology. Sep. 2005;103(3):600-5. [pmid: 16129986].
386 Nathanson L, Adib R. Randomized trial of open and laparoscopic inguinal hernia repair. [abstract S81]. Surg Endosc. 1996;10:192.
387 Nazir M, Saebø A. Contralateral inguinal hernial development and ipsilateral recurrence following unilateral hernial repair in infants and children. Acta Chir Belg. Feb. 1996;96(1):28-30. [pmid: 8629384].
388 Neagu S, Costea R, Badea V, et al. Not “gold standard” but “gold option” of inguinal hernia repair. Hernia in the 21st century. Toronto. 2000:182.
389 Negro P, Basile F, Brescia A, et al. Open tension-free Lichtenstein repair of inguinal hernia: use of fibrin glue versus sutures for mesh fixation. Hernia. Feb. 2011;15(1):7-14. [pmid: 20676711].
390 Newman L III, Eubanks S, Mason E, et al. Is laparoscopic herniorrhaphy an effective alternative to open hernia repair?. J Laparoendosc Surg. 1993;3(2):121-8. [pmid: 8518463].
391 Nicholson T, Tiruchelvam V. Comparison of laparoscopic vs open modified Shouldice technique in inguinal hernia repair. J Soc Laparoendosc Surg. Jan-Mar. 1999;3(1):39-43. [pmid: 10323168].
392 Nienhuijs SW, Remijn EE, Rosman C. Hernia repair in elderly patients under unmonitored local anaesthesia is feasible. Hernia. Oct. 2005;9(3):218-22. [pmid: 15703856].
393 Nienhuijs S, Staal E, Strobbe L, et al. Chronic pain after mesh repair of inguinal hernia: a systematic review. Am J Surg. Sep. 2007;194(3):394-400. [pmid: 17693290].
394 Nishimura S, Yoshikawa K, Kawamura T, et al. The mesh plug technique for adult inguinal herniation. Int Surg. Apr-Jun. 2000;85(2):163-6. [pmid: 11071336].
395 Nixon SJ, Jawaid H. Recurrence after inguinal hernia repair at ten years by open darn, open mesh and TEP--no advantage with mesh. Surgeon. Apr. 2009;7(2):71-4. [pmid: 19408796].
396 Niyogi A, Tahim AS, Sherwood WJ, et al. A comparative study examining open inguinal herniotomy with and without hernioscopy to laparoscopic inguinal hernia repair in a pediatric population. Pediatr Surg Int. Apr. 2010;26(4):387-92. [pmid: 20143077].
397 Nordin P, Bartelmess P, Jansson C, et al. Randomized trial of Lichtenstein versus Shouldice hernia repair in general surgical practice. Br J Surg. Jan. 2002;89(1):45-9. [pmid: 11851662].
398 Nordin P, Zetterstrom H, Gunnarsson U, et al. Local, regional, or general anaesthesia in groin hernia repair: multicentre randomised trial. Lancet. Sep. 13. 2003;362(9387):853-8. [pmid: 13678971].
399 Nordin P, Hernell H, Unosson M, et al. Type of anaesthesia and patient acceptance in groin hernia repair: a multicentre randomised trial. Hernia. Aug. 2004;8(3):220-5. [pmid: 15235937].
400 Nordin P, Zetterstrom H, Carlsson P, et al. Cost-effectiveness analysis of local, regional and general anaesthesia for inguinal hernia repair using data from a randomized clinical trial. Br J Surg. Apr. 2007;94(4):500-5. [pmid: 17330241].
401 Nordin P. Lichtenstein versus Shouldice. [unpublished].
402 Nyhus LM. Individualization of hernia repair: a new era. Surgery. Jul. 1993;114(1):1-2. [pmid: 8356511].
403 Oberg E, Jacobsen B, Rosenberg J. Chronic pain and recurrence after laparoscopic inguinal herniorrhaphy. Surg Laparosc Endosc Percutan Tech. Sep. 2005;15(5):267-9. discussion 269-70. [pmid: 16215484].
404 Obrist C, Brunner W, Schirnhofer J, et al. SIL-TAPP versus Lichtenstein repair: a matched-pairs analysis. Eur Surg. Jun. 2011;43(Suppl 241):37.
405 O'Dwyer PJ, Serpell MG, Millar K, et al. Local or general anesthesia for open hernia repair: a randomized trial. Ann Surg. Apr. 2003;237(4):574-9. [pmid: 12677155].
406 Oehlenschlager J, Hjorne FP, Albers M, et al. Fewer urological complications after laparoscopic inguinal hernia repair without indwelling catheter. Dan Med Bull. Sep. 2010;57(9):A4176. [pmid: 20816016].
407 Ohana G, Powsner E, Melki Y, et al. Simultaneous repair of bilateral inguinal hernias: a prospective, randomized study of single versus double mesh laparoscopic totally extraperitoneal repair. Surg Laparosc Endosc Percutan Tech. Feb. 2006;16(1):12-7. [pmid: 16552372].
408 O'Hanlon JJ, McCleane G, Muldoon T. Preoperative application of piroxicam gel compared to a local anaesthetic field block for postoperative analgesia. Acta Anaesthesiol Scand. Jul. 1996;40(6):715-8. [pmid: 8836267].
409 O'Riordain DS, Kelly P, Horgan PG, et al. A randomized controlled trial of extraperitoneal bupivacaine analgesia in laparoscopic hernia repair. Am J Surg. Sep. 1998;176(3):254-7. [pmid: 9776153].
410 Osuigwe AN, Ekwunife CN, Ihekowba CH. Use of prophylactic antibiotics in a paediatric day-case surgery at NAUTH, Nnewi, Nigeria: a randomized double-blinded study. Trop Doct. Jan. 2006;36(1):42-4. [pmid: 16483435].
411 Ozcengiz D, Gunduz M, Ozbek H, et al. Comparison of caudal morphine and tramadol for postoperative pain control in children undergoing inguinal herniorrhaphy. Paediatr Anaesth. Jul. 2001;11(4):459-64. [pmid: 11442865].
412 Ozgediz D, Roayaie K, Lee H, et al. Subcutaneous endoscopically assisted ligation (SEAL) of the internal ring for repair of inguinal hernias in children: report of a new technique and early results. Surg Endosc. Aug. 2007;21(8):1327-31. [pmid: 17356946].
413 Ozgun H, Kurt MN, Kurt I, et al. Comparison of local, spinal, and general anaesthesia for inguinal herniorrhaphy. Eur J Surg. 2002;168(8-9):455-9. [pmid: 12549684].
414 Ozkan D, Akkaya T, Comert A, et al. Paravertebral block in inguinal hernia surgeries: two segments or 4 segments. Reg Anesth Pain Med. Jul-Aug. 2009;34(4):312-5. [pmid: 19574864].
415 Ozmen MM, Moran M, Ozalp N, et al. Tep vs open preperitoneal hernia repairs. Surg Endosc. Mar. 2011;25:S8.
416 Paajanen H. Groin hernia repair under local anaesthesia: effect of surgeon's training level on long-term results. Ambul Surg. Dec. 2003;10(3):143-6.
417 Paajanen H, Scheinin T, Vironen J. Commentary: nationwide analysis of complications related to inguinal hernia surgery in Finland: a 5 year register study of 55,000 operations. Am J Surg. Jun. 2010;199(6):746-51. [pmid: 20609720].
418 Page B, Paterson C, Young D, et al. Pain from primary inguinal hernia and the effect of repair on pain. Br J Surg. Oct. 2002;89(10):1315-8. [pmid: 12296904].
419 Paily A, Thornton M. Chronic pain following a Lichtenstein inguinal hernia repair: a clinical and legal dilemma. ANZ J Surg. Jul. 2009;79(7-8):517-20. [pmid: 19694658].
420 Pala Y, Ozcan M, Dikmeer G, et al. Selective spinal anesthesia for inguinal herniorrhaphy. Saudi Med J. Nov. 2009;30(11):1444-9. [pmid: 19882058].
421 Panos RG, Beck DE, Maresh JE, et al. Preliminary results of a prospective randomized study of Cooper's ligament versus Shouldice herniorrhaphy technique. Surg Gynecol Obstet. Oct. 1992;175(4):315-9. [pmid: 1411887].
422 Panton ON, Panton RJ. Laparoscopic hernia repair. Am J Surg. May. 1994;167(5):535-7. [pmid: 8185043].
423 Papachristou EA, Mitselou MF, Finokaliotis ND. Surgical outcome and hospital cost analyses of laparoscopic and open tension-free hernia repair. Hernia. Jul. 2002;6(2):68-72. [pmid: 12152642].
424 Papaziogas B, Koutelidakis IM, Giamarellos-Bourboulis EJ, et al. Tension-free vs. Andrews technique. Prostaglandins Leukot Essent Fatty Acids. Oct. 2004;71(4):221-5. [pmid: 15301792].
425 Pappalardo G, Guadalaxara A, Illomei G, et al. Prevention of postherniorrhaphy persistent pain: results of a prospective study. Int Surg. Oct-Dec. 1999;84(4):350-3. [pmid: 10667816].
426 Pardieck DA. Laparoscopic inguinal hernia repairs in men in a community hospital setting using the TAPP approach. J S C Med Assoc. Aug. 1998;94(8):345-50. [pmid: 9735570].
427 Passariello M, Almenrader N, Canneti A, et al. Caudal analgesia in children: S(+)-ketamine vs S(+)-ketamine plus clonidine. Paediatr Anaesth. Oct. 2004;14(10):851-5. [pmid: 15385014].
428 Paul A, Troidl H, Williams JI, et al. Randomized trial of modified Bassini versus Shouldice inguinal hernia repair. The Cologne Hernia Study Group. Br J Surg. Oct. 1994;81(10):1531-4. [pmid: 7646633].
429 Pawanindra Lal, Philips P, Chander J, et al. Is unilateral laparoscopic TEP inguinal hernia repair a job half done? The case for bilateral repair. Surg Endosc. Jul. 2010;24(7):1737-45. [pmid: 20135181].
430 Payne KA, Coetzee AR, Mattheyse FJ, et al. Behavioural changes in children following minor surgery--is premedication beneficial. Acta Anaesthesiol Belg. 1992;43(3):173-9. [pmid: 1449049].
431 Payne J, Izawa M, Glen P, et al. Laparoscopic or tension-free inguinal hernia repair? A cost/benefit analysis of 200 prospectively randomized patients. [abstract S128]. Surg Endosc. 1996;10:204.
432 Peiper C, Tons C, Schippers E, et al. Local versus general anesthesia for Shouldice repair of the inguinal hernia. World J Surg. Nov-Dec. 1994;18(6):912-5. discussion 915-6. [pmid: 7846918].
433 Pelissier EP. Inguinal hernia: preperitoneal placement of a memory-ring patch by anterior approach. Preliminary experience. Hernia. Jun. 2006;10(3):248-52. [pmid: 16758150].
434 Perez AR, Roxas MF, Hilvano SS. A randomized, double-blind, placebo-controlled trial to determine effectiveness of antibiotic prophylaxis for tension-free mesh herniorrhaphy. J Am Coll Surg. Mar. 2005;200(3):393-7. discussion 397-8. [pmid: 15737849].
435 Perko Z, Rakic M, Pogorelic Z, et al. Laparoscopic transabdominal preperitoneal approach for inguinal hernia repair: a five-year experience at a single center. Surg Today. Feb. 2011;41(2):216-21. [pmid: 21264757].
436 Pessaux P, Lermite E, Blezel E, et al. Predictive risk score for infection after inguinal hernia repair. Am J Surg. Aug. 2006;192(2):165-71. [pmid: 16860624].
437 Petóházi A, Simon E, Kelemen O, et al. The laparoscopic technique for bilateral inguinal hernias. Acta Chir Hung. 1999;38(2):197-9. [pmid: 10596329].
438 Picchio M, Palimento D, Attanasio U, et al. Randomized controlled trial of preservation or elective division of ilioinguinal nerve on open inguinal hernia repair with polypropylene mesh. Arch Surg. Jul. 2004;139(7):755-8. discussion 759. [pmid: 15249409].
439 Pierides G, Vironen J. A prospective randomized clinical trial comparing the prolene hernia system and the Lichtenstein patch technique for inguinal hernia repair in long term: 2- And 5-year results. Am J Surg. Aug. 2011;202(2):188-93. [pmid: 21810499].
440 Platt R, Zaleznik DF, Hopkins CC, et al. Perioperative antibiotic prophylaxis for herniorrhaphy and breast surgery. N Engl J Med. Jan. 18. 1990;322(3):153-60. [pmid: 2403655].
441 Podolsky ER, Curcillo PG 2nd. Single port access (SPA) surgery--a 24-month experience. J Gastrointest Surg. May. 2010;14(5):759-67. [pmid: 20155330].
442 Polat C, Kahraman A, Yilmaz S, et al. A comparison of the oxidative stress response and antioxidant capacity of open and laparoscopic hernia repairs. J Laparoendosc Adv Surg Tech A. Jun. 2003;13(3):167-73. [pmid: 12855098].
443 Poobalan AS, Bruce J, King PM, et al. Chronic pain and quality of life following open inguinal hernia repair. Br J Surg. Aug. 2001;88(8):1122-6. [pmid: 11488800].
444 Poobalan AS, Bruce J, Smith WC, et al. A review of chronic pain after inguinal herniorrhaphy. Clin J Pain. Jan-Feb. 2003;19(1):48-54. [pmid: 12514456].
445 Pradhan B, Bajracharya GR. Midazolam for caudal analgesia in children: comparison with caudal bupivacaine. Kathmandu Univ Med J (KUMJ). Apr-Jun. 2008;6(2):166-72. [pmid: 18769080].
446 Praveen S, Rohaizak M. Local antibiotics are equivalent to intravenous antibiotics in the prevention of superficial wound infection in inguinal hernioplasty. Asian J Surg. Jan. 2009;32(1):59-63. [pmid: 19321405].
447 Prieto-Díaz-Chávez E, Medina-Chávez JL, González-Ojeda A, et al. Tension-free hernioplasty versus conventional hernioplasty for inguinal hernia repair. Surg Today. 2005;35(12):1047-53. [pmid: 16341485].
448 Prieto-Diaz-Chavez E, Medina-Chavez JL, Anaya-Prado R. A cost-effectiveness analysis of tension-free versus shouldice inguinal hernia repair: a randomized double-blind clinical trial. Hernia. Jun. 2009;13(3):233-8. [pmid: 19225858].
449 Prior MJ, Williams EV, Shukla HS, et al. Prospective randomized controlled trial comparing Lichtenstein with modified Bassini repair of inguinal hernia. J R Coll Surg Edinb. Apr. 1998;43(2):82-6. [pmid: 9621526].
450 Pullyblank AM, Carney L, Braddon F, et al. Laparoscopic inguinal hernia repair: a NICE operation. J R Coll Surg Edinb. Aug. 2002;47(4):630-3. [pmid: 12363190].
451 Purkayastha S, Chow A, Athanasiou T, et al. Inguinal hernia. Clin Evid (Online). 2008;2008. [pmid: 19445744].
452 Quilici PJ, Greaney EM Jr, Quilici J, et al. Laparoscopic inguinal hernia repair results: 131 Cases. Am Surg. 1993;59(12):824-30. [pmid: 8256936].
453 Quilici PJ, Greaney EM, Quilici J, et al. Transabdominal preperitoneal laparoscopic inguinal herniorrhaphy: results of 509 repairs. Am Surg. Oct. 1996;62(10):849-52. [pmid: 8813169].
454 Quilici PJ, Greaney EM Jr, Quilici J, et al. Laparoscopic inguinal hernia repair: optimal technical variations and results in 1700 cases. Am Surg. Sep. 2000;66(9):848-52. [pmid: 10993614].
455 Rahr HB, Bendix J, Ahlburg P, et al. Coagulation, inflammatory, and stress responses in a randomized comparison of open and laparoscopic repair of recurrent inguinal hernia. Surg Endosc. Mar. 2006;20(3):468-72. [pmid: 16437269].
456 Rajapandian S, Senthilnathan P, Gupta A, et al. Laparoscopic totally extraperitoneal repair of inguinal hernia using two-hand approach--a gold standard alternative to open repair. J Indian Med Assoc. Oct. 2010;108(10):652-4. [pmid: 21510548].
457 Ramon JM, Carull X, Hidalgo JM, et al. Study of quality of life in relation with the health after the surgery of the endoscopic inguinal hernia versus conventional. Br J Surg. 1998;85(Suppl II):18.
458 Ramshaw BJ, Tucker JG, Mason EM, et al. A comparison of transabdominal preperitoneal (TAPP) and total extraperitoneal approach (TEPA) laparoscopic herniorrhaphies. Am Surg. Mar. 1995;61(3):279-83. [pmid: 7887547].
459 Ramshaw BJ, Tucker JG, Conner T, et al. A comparison of the approaches to laparoscopic herniorrhaphy. Surg Endosc. Jan. 1996;10(1):29-32. [pmid: 8711601].
460 Ramshaw BJ, Tucker J, Duncan T, et al. The effect of previous lower abdominal surgery on performing the total extraperitoneal approach to laparoscopic herniorrhaphy. Am Surg. Apr. 1996;62(4):292-4. [pmid: 8600850].
461 Ramshaw BJ, Tucker JG, Duncan TD, et al. Technical considerations of the different approaches to laparoscopic herniorrhaphy: an analysis of 500 cases. Am Surg. Jan. 1996;62(1):69-72. [pmid: 8540650].
462 Ravichandran D, Kalambe BG, Pain JA. Pilot randomized controlled study of preservation or division of ilioinguinal nerve in open mesh repair of inguinal hernia. Br J Surg. Sep. 2000;87(9):1166-7. [pmid: 10971422].
463 Richards SK, Vipond MN, Earnshaw JJ. Review of the management of recurrent inguinal hernia. Hernia. May. 2004;8(2):144-8. [pmid: 14685827].
464 Rizk N, Champault G, Lauroy J, et al. Laparoscopic preperitoneal hernia repair vs shouldice herniorrhaphy: preliminary results of a prospective randomized trial of 242 cases. Br J Surg. 1994;81(Suppl):70-1.
465 Rogers DA, Hatley RM, Howell CG Jr. A prospective, randomized comparison of traditional and laparoscopic inguinal exploration in children. Am Surg. Feb. 1998;64(2):119-21. [pmid: 9486881].
466 Romsing J, Mysager S, Vilmann P, et al. Postoperative analgesia is not different after local vs systemic administration of meloxicam in patients undergoing inguinal hernia repair. Can J Anaesth. Nov. 2001;48(10):978-84. [pmid: 11698316].
467 Ron O, Eaton S, Pierro A. Systematic review of the risk of developing a metachronous contralateral inguinal hernia in children. Br J Surg. Jul. 2007;94(7):804-11. [pmid: 17571299].
468 Rose K, Wright D, Ward T, et al. Tension-free mesh hernia repair: recovery and recurrence after one year. Ann R Coll Surg Engl. Sep. 1999;81(5):329-32. [pmid: 10645175].
469 Rosen M, Garcia-Ruiz A, Malm J, et al. Laparoscopic hernia repair enhances early return of physical work capacity. Surg Laparosc Endosc Percutan Tech. Feb. 2001;11(1):28-33. [pmid: 11269552].
470 Rosenberg J. Pediatric inguinal hernia repair-a critical appraisal. Hernia. Apr. 2008;12(2):113-5. [pmid: 18060351].
471 Rowbotham DJ, Peacock JE, Jones RM, et al. Comparison of remifentanil in combination with isoflurane or propofol for short-stay surgical procedures. Br J Anaesth. Jun. 1998;80(6):752-5. [pmid: 9771302].
472 Rudkin GE, Maddern GJ. Peri-operative outcome for day-case laparoscopic and open inguinal hernia repair. Anaesthesia. Jul. 1995;50(7):586-9. [pmid: 7653754].
473 Ryhanen P, Adamski J, Puhakka K, et al. Postoperative pain relief in children. A comparison between caudal bupivacaine and intramuscular diclofenac sodium. Anaesthesia. Jan. 1994;49(1):57-61. [pmid: 7906104].
474 Rukas R, Stupas K, Rukiene A. The comparison of LIchtenstein and Bassini repairs for inguinal hernia. Hernia in the 21st century. Toronto. 2000:270.
475 Rulli F, Percudani M, Muzi M, et al. From Bassini to tension-free mesh hernia repair. Review of 1409 consecutive cases. G Chir. Jun-Jul. 1998;19(6-7):285-9. [pmid: 9707835].
476 Rutkow IM, Robbins AW. “Tension-free” inguinal herniorrhaphy: a preliminary report on the “mesh plug” technique. Surgery. Jul. 1993;114(1):3-8. [pmid: 8356522].
477 Rutkow IM, Robbins AW. Mesh plug hernia repair: a follow-up report. Surgery. May. 1995;117(5):597-8. [pmid: 7740435].
478 Rutkow IM. Demographic and socioeconomic aspects of hernia repair in the United States in 2003. Surg Clin North Am. Oct. 2003;83(5):1045-51. v. vi. [pmid: 14533902].
479 Saad SA, Goldfarb MA, Danikas D. Groin laparoscopy in pediatric patients with clinical unilateral inguinal hernia: an improved technique using the bronchoscope. Pediatr Endosurg Innov Tech. 1999;3(2):59-65.
480 Saad S, Mansson J, Saad A, et al. Ten-year review of groin laparoscopy in 1001 pediatric patients with clinical unilateral inguinal hernia: an improved technique with transhernia multiple-channel scope. J Pediatr Surg. May. 2011;46(5):1011-4. [pmid: 21616272].
481 Saadawy I, Boker A, Elshahawy MA, et al. Effect of dexmedetomidine on the characteristics of bupivacaine in a caudal block in pediatrics. Acta Anaesthesiol Scand. Feb. 2009;53(2):251-6. [pmid: 19076110].
482 Saggar VR, Sarangi R. Laparoscopic totally extraperitoneal repair of inguinal hernia: a policy of selective mesh fixation over a 10-year period. J Laparoendosc Adv Surg Tech A. Apr. 1. 2008;18(2):209-12. [pmid: 18373445].
483 Salameh JR, Sweeney JF, Graviss EA, et al. Laparoscopic ventral hernia repair during the learning curve. Hernia. Dec. 2002;6(4):182-7. [pmid: 12424598].
484 Sale SM, Read JA, Stoddart PA, et al. Prospective comparison of sevoflurane and desflurane in formerly premature infants undergoing inguinal herniotomy. Br J Anaesth. Jun. 2006;96(6):774-8. [pmid: 16648152].
485 Sanabria A, Dominguez LC, Valdivieso E, et al. Prophylactic antibiotics for mesh inguinal hernioplasty: a meta-analysis. Ann Surg. Mar. 2007;245(3):392-6. [pmid: 17435546].
486 Sanchez-Manuel FJ, Lozano-García J, Seco-Gil JL. Antibiotic prophylaxis for hernia repair. Cochrane Database of Systematic Reviews. [internet]. Hoboken (NJ). John Wiley & Sons, Ltd. 2007;(3). 2010 Jul 2. ]. [Art. No.: CD003769]. Available:. [doi: 10.1002/14651858.CD003769.pub3].
487 Sandbichler P, Draxl H, Gstir H, et al. Laparoscopic repair of recurrent inguinal hernias. Am J Surg. Mar. 1996;171(3):366-8. [pmid: 8615475].
488 Sondenaa K, Nesvik I, Breivik K, et al. Long-term follow-up of 1059 consecutive primary and recurrent inguinal hernias in a teaching hospital. Eur J Surg. Feb. 2001;167(2):125-9. [pmid: 11266252].
489 Santoro E, Agresta F, Buscaglia F, et al. Preliminary experience using fibrin glue for mesh fixation in 250 patients undergoing minilaparoscopic transabdominal preperitoneal hernia repair. J Laparoendosc Adv Surg Tech A. Feb. 2007;17(1):12-5. [pmid: 17362171].
490 Saranga Bharathi R, Arora M, Baskaran V. Pediatric inguinal hernia: laparoscopic versus open surgery. JSLS. Jul-Sep. 2008;12(3):277-81. [pmid: 18765052].
491 Saranga Bharathi R, Arora M, Baskaran V. Minimal access surgery of pediatric inguinal hernias: a review. Surg Endosc. Aug. 2008;22(8):1751-62. [pmid: 18398652].
492 Sarli L, Villa F, Marchesi F. Hernioplasty and simultaneous laparoscopic cholecystectomy: a prospective randomized study of open tension-free versus laparoscopic inguinal hernia repair. Surgery. May. 2001;129(5):530-6. [pmid: 11331444].
493 Savarise MT, Simpson JP, Moore JM, et al. Improved functional outcome and more rapid return to normal activity following laparoscopic hernia repair. Surg Endosc. Jun. 2001;15(6):574-8. [pmid: 11591943].
494 Schafer M, Vuilleumier H, Di Mare L, et al. Fibrin sealant for mesh fixation in endoscopic inguinal hernia repair: is there enough evidence for its routine use?. Surg Laparosc Endosc Percutan Tech. Aug. 2010;20(4):205-12. [pmid: 20729686].
495 Schindler M, Swann M, Crawford M. A comparison of postoperative analgesia provided by wound infiltration or caudal analgesia. Anaesth Intensive Care. Feb. 1991;19(1):46-9. [pmid: 2012294].
496 Schmedt CG, Leibl BJ, Bittner R. Endoscopic inguinal hernia repair in comparison with Shouldice and Lichtenstein repair. A systematic review of randomized trials. Dig Surg. 2002;19(6):511-7. [pmid: 12499747].
497 Schmedt CG, Sauerland S, Bittner R. Comparison of endoscopic procedures vs Lichtenstein and other open mesh techniques for inguinal hernia repair: a meta-analysis of randomized controlled trials. Surg Endosc. Feb. 2005;19(2):188-99. [pmid: 15578250].
498 Schmidt SC, Langrehr JM. Autologous fibrin sealant (Vivostat) for mesh fixation in laparospic transabdominal preperitoneal hernia repair. Endoscopy. Aug. 2006;38(8):841-4. [pmid: 17001576].
499 Schneider BE, Castillo JM, Villegas L, et al. Laparoscopic totally extraperitoneal versus Lichtenstein herniorrhaphy: cost comparison at teaching hospitals. Surg Laparosc Endosc Percutan Tech. Aug. 2003;13(4):261-7. [pmid: 12960790].
500 Schrenk P, Bettelheim P, Woisetschlager R, et al. Metabolic responses after laparoscopic or open hernia repair. Surg Endosc. Jun. 1996;10(6):628-32. [pmid: 8662400].
501 Schroder DM, Lloyd LR, Boccaccio JE, et al. Inguinal hernia recurrence following preperitoneal Kugel patch repair. Am Surg. Feb. 2004;70(2):132-6. discussion 136. [pmid: 15011915].
502 Schultz LS. Laparoscopic vs inguinal hernia repairs. Outcomes and costs. Surg Endosc. Dec. 1995;9(12):1307-11. [pmid: 8629217].
503 Schurz JW, Arregui ME, Hammond JC. Open vs laparoscopic hernia repair. Analysis of costs, charges, and outcomes. Surg Endosc. Dec. 1995;9(12):1311-7. [pmid: 8629218].
504 Schwab R, Eissele S, Bruckner UB, et al. Systemic inflammatory response after endoscopic (TEP) vs Shouldice groin hernia repair. Hernia. Aug. 2004;8(3):226-32. [pmid: 15042432].
505 Schwab R, Willms A, Kroger A, et al. Less chronic pain following mesh fixation using a fibrin sealant in TEP inguinal hernia repair. Hernia. Jun. 2006;10(3):272-7. [pmid: 16554980].
506 Schwab R, Schumacher O, Junge K, et al. Biomechanical analyses of mesh fixation in TAPP and TEP hernia repair. Surg Endosc. Mar. 2008;22(3):731-8. [pmid: 17623239].
507 Schwobel MG, Schramm H, Gitzelmann CA. The infantile inguinal hernia - a bilateral disease?. Pediatr Surg Int. 1999;15(2):115-8. [pmid: 10079343].
508 Scott AD, Phillips A, White JB, et al. Analgesia following inguinal herniotomy or orchidopexy in children: a comparison of caudal and regional blockade. J R Coll Surg Edinb. Jun. 1989;34(3):143-5. [pmid: 2810163].
509 Scott N, Go PM, Graham P, et al. Open Mesh versus non-Mesh for groin hernia repair. Cochrane Database of Systematic Reviews. [internet]. Hoboken (NJ). John Wiley & Sons, Ltd. 2001;(3). 2010 Jul 2. ]. [Art. No.: CD002197]. Available:. [doi: 10.1002/14651858.CD002197]. [pmid: 12519568].
510 Shah BC, Goede MR, Bayer R, et al. Does type of mesh used have an impact on outcomes in laparoscopic inguinal hernia?. Am J Surg. Dec. 2009;198(6):759-64. [pmid: 19969126].
511 Shah NR, Mikami DJ, Cook C, et al. A comparison of outcomes between open and laparoscopic surgical repair of recurrent inguinal hernias. Surg Endosc. 2011. Feb. 7. [pmid: 21298523].
512 Shamim SM, Shamim MS, Jaffary SA, et al. Trends in the management of inguinal hernia in Karachi, Pakistan: a survey of practice patterns. Singapore Med J. Jun. 2006;47(6):512-7. [pmid: 16752020].
513 She WH, Lo OS, Fan JK, et al. Needlescopic totally extraperitoneal hernioplasty for unilateral inguinal hernia in adult patients. Asian J Surg. Jan. 2011;34(1):23-7. [pmid: 21515209].
514 Shehata SM, El Attar AA, Attia MA, et al. Prospective assessment of laparoscopic herniotomy in children: tertiary center experience from developing country. J Laparoendosc Adv Surg Tech A. May. 2011;21(4):A55.
515 Sherwinter DA. Transitioning to single-incision laparoscopic inguinal herniorrhaphy. J Soc Laparoendosc Surg. Jul-Sep. 2010;14(3):353-7. [pmid: 21333187].
516 Simons MP, Kleijnen J, van Geldere D, et al. Role of the Shouldice technique in inguinal hernia repair: a systematic review of controlled trials and a meta-analysis. Br J Surg. Jun. 1996;83(6):734-8. [pmid: 8696728].
517 Sinclair R, Cassuto J, Hogstrom S, et al. Topical anesthesia with lidocaine aerosol in the control of postoperative pain. Anesthesiology. Jun. 1988;68(6):895-901. [pmid: 3288007].
518 Sinha R, Sharma N, Dhobal D, et al. Laparoscopic total extraperitoneal repair versus anterior preperitoneal repair for inguinal hernia. Hernia. Apr. 2006;10(2):187-91. [pmid: 16479362].
519 Smedberg SG, Broome AE, Gullmo A. Ligation of the hernial sac. Surg Clin North Am. Apr. 1984;64(2):299-306. [pmid: 6729671].
520 Smeds S, Kald A, Lofstrom L. Chronic pain after open inguinal hernia repair: a longitudinal self-assessment study. Hernia. Jun. 2010;14(3):249-52. [pmid: 20052509].
521 Smith JR, Demers ML, Pollack R, et al. Prospective comparison between laparoscopic preperitoneal herniorrhaphy and open mesh herniorrhaphy. Am Surg. Feb. 2001;67(2):115-7. discussion 117-8. [pmid: 11243531].
522 Somri M, Gaitini L, Vaida S, et al. Postoperative outcome in high-risk infants undergoing herniorrhaphy: comparison between spinal and general anaesthesia. Anaesthesia. Aug. 1998;53(8):762-6. [pmid: 9797520].
523 Song D, Greilich NB, White PF, et al. Recovery profiles and costs of anesthesia for outpatient unilateral inguinal herniorrhaphy. Anesth Analg. Oct. 2000;91(4):876-81. [pmid: 11004041].
524 Sosa JL, Puente I, Markley M, et al. A modified technique of laparoscopic herniorrhaphy: operative approach and early results. Int Surg. Oct-Dec. 1994;79(4):300-3. [pmid: 7713695].
525 Spittal MJ, Hunter SJ. A comparison of bupivacaine instillation and inguinal field block for control of pain after herniorrhaphy. Ann R Coll Surg Engl. Mar. 1992;74(2):85-8. [pmid: 1567148].
526 Splinter WM, Bass J, Komocar L. Regional anaesthesia for hernia repair in children: local vs caudal anaesthesia. Can J Anaesth. Mar. 1995;42(3):197-200. [pmid: 7743568].
527 Srsen D, Druzijanic N, Pogorelic Z, et al. Quality of life analysis after open and laparoscopic inguinal hernia repair--retrospective study. Hepatogastroenterology. Nov-Dec. 2008;55(88):2112-5. [pmid: 19260487].
528 Staerkle RF, Buchli C, Villiger P. Patient satisfaction, hernia recurrence rate, and chronic pain 10 years after endoscopic total extraperitoneal inguinal hernia repair. Surg Laparosc Endosc Percutan Tech. Oct. 2009;19(5):405-9. [pmid: 19851272].
529 Stark E, Oestreich K, Wendl K, et al. Nerve irritation after laparoscopic hernia repair. Surg Endosc. Sep. 1999;13(9):878-81. [pmid: 10449843].
530 Steinau G, Dreuw B, Schleef J, et al. Recommendations for treatment of contralateral inguinal hernias in children. Hernia. 1999;3(2):53-6.
531 Stengel D, Bauwens K, Ekkernkamp A. Recurrence risks in randomized trials of laparoscopic versus open inguinal hernia repair: to pool or not to pool (this is not the question). Langenbecks Arch Surg. Nov. 2004;389(6):492-8. [pmid: 15538621].
532 Stoker DL, Spiegelhalter DJ, Singh R, et al. Laparoscopic versus open inguinal hernia repair: randomised prospective trial. Lancet. May. 21. 1994;343(8908):1243-5. [pmid: 7910272].
533 Stoppa R. Hernias of the abdominal wall. Chevrel JP, editor. Hernias and surgery of the abdominal wall. Berlin. Springer. 1998:171-277.
534 Stylopoulos N, Gazelle GS, Rattner DW. A cost--utility analysis of treatment options for inguinal hernia in 1,513,008 adult patients. Surg Endosc. Feb. 2003;17(2):180-9. [pmid: 12415334].
535 Subwongcharoen S. Outcome of inguinal hernia repair total extraperitoneal laparoscopic hernia repair versus open tension free repair (Lichtenstein technique). J Med Assoc Thai. Oct. 2002;85(10):1100-3. [pmid: 12501902].
536 Sucullu I, Filiz AI, Sen B, et al. The effects of inguinal hernia repair on testicular function in young adults: a prospective randomized study. Hernia. Apr. 2010;14(2):165-9. [pmid: 19937077].
537 Surana R, Puri P. Is contralateral exploration necessary in infants with unilateral inguinal hernia?. J Pediatr Surg. Aug. 1993;28(8):1026-7. [pmid: 8229590].
538 Tagaya N, Kita J, Kogure H. Laparoscopic transabdominal preperitoneal herniorrhaphy using abdominal wall-lifting method under regional anesthesia: a preliminary report. J Laparoendosc Surg. Aug. 1995;5(4):215-20. [pmid: 7579672].
539 Tai HC, Lin CD, Chung SD, et al. A comparative study of standard versus laparoendoscopic single-site surgery (LESS) totally extraperitoneal (TEP) inguinal hernia repair. Surg Endosc. Sep. 2011;25(9):2879-83. [pmid: 21667210].
540 Takahara T, Uyama I, Ogiwara H, et al. Inflammatory responses in open versus laparoscopic herniorrhaphy. J Laparoendosc Surg. Oct. 1995;5(5):317-26. [pmid: 8845506].
541 Tamaddon H, Phillips JD, Nakayama DK. Laparoscopic evaluation of the contralateral groin in pediatric inguinal hernia patients: a comparison of 70- and 120-degree endoscopes. J Laparoendosc Adv Surg Tech A. Dec. 2005;15(6):653-60. [pmid: 16366878].
542 Tamme C, Garde N, Klingler A, et al. Totally extraperitoneal inguinal hernioplasty with titanium-coated lightweight polypropylene mesh: early results. Surg Endosc. Aug. 2005;19(8):1125-9. [pmid: 16021367].
543 Tanovic H, Mesihovic R, Muhovic S. Randomized trial of TEP laparoscopic hernioplasty versus Bassni inguinal hernia repair. Med Arh. 2005;59(4):214-6. [pmid: 16018384].
544 Tanphiphat C, Tanprayoon T, Sangsubhan C, et al. Laparoscopic vs open inguinal hernia repair. A randomized, controlled trial. Surg Endosc. Jun. 1998;12(6):846-51. [pmid: 9602004].
545 Tantia O, Jain M, Khanna S, et al. Laparoscopic repair of recurrent groin hernia: results of a prospective study. Surg Endosc. Apr. 2009;23(4):734-8. [pmid: 18622546].
546 Taylor EW, Byrne DJ, Leaper DJ, et al. Antibiotic prophylaxis and open groin hernia repair. World J Surg. Oct. 1997;21(8):811-4. discussion 814-5. [pmid: 9327671].
547 Teasdale C, McCrum AM, Williams NB, et al. A randomised controlled trial to compare local with general anaesthesia for short-stay inguinal hernia repair. Ann R Coll Surg Engl. Jul. 1982;64(4):238-42. [pmid: 7046604].
548 Terzi C, Kilic D, Unek T, et al. Single-dose oral ciprofloxacin compared with single-dose intravenous cefazolin for prophylaxis in inguinal hernia repair: a controlled randomized clinical study. J Hosp Infect. Aug. 2005;60(4):340-7. [pmid: 16002019].
549 Tetik C, Arregui ME, Dulucq JL, et al. Complications and recurrences associated with laparoscopic repair of groin hernias. A multi-institutional retrospective analysis. Surg Endosc. Nov. 1994;8(11):1316-22. discussion 1322-. [pmid: 7831605].
550 Thaha MA, Sanjay P, Woodward A, et al. Anaesthetic techniques for open inguinal hernia repair in adults. Cochrane Database of Systematic Reviews. [internat]. Hoboken (NJ). John Wiley & Sons, Ltd. 2007;(3). 2010 Jul 2. ]. [Art. No.: CD006684]. Available:. [doi: 10.1002/14651858.CD006684].
551 Thapar V, Rao P, Deshpande A, et al. Shouldice's herniorrhaphy versus Moloney's darn herniorrhaphy in young patients (a prospective randomised study). J Postgrad Med. Jan-Mar. 2000;46(1):9-12. [pmid: 10855070].
552 Thill RH, Hopkins WM. The use of Mersilene mesh in adult inguinal and femoral hernia repairs: a comparison with classic techniques. Am Surg. Aug. 1994;60(8):553-6. discussion 556-7. [pmid: 8030807].
553 Topal B, Hourlay P. Totally preperitoneal endoscopic inguinal hernia repair. Br J Surg. Jan. 1997;84(1):61-3. [pmid: 9043454].
554 Topart P, Vandenbroucke F, Lozac'h P. Tisseel versus tack staples as mesh fixation in totally extraperitoneal laparoscopic repair of groin hernias: a retrospective analysis. Surg Endosc. May. 2005;19(5):724-7. [pmid: 15759187].
555 Toufique Ehsan M, Ng AT, Chung PH, et al. Laparoscopic hernioplasties in children: the implication on contralateral groin exploration for unilateral inguinal hernias. Pediatr Surg Int. Sep. 2009;25(9):759-62. [pmid: 19652984].
556 Toy FK, Moskowitz M, Smoot RT Jr, et al. Results of a prospective multicenter trial evaluating the ePTFE peritoneal onlay laparoscopic inguinal hernioplasty. J Laparoendosc Surg. Dec. 1996;6(6):375-86. [pmid: 9025021].
557 Tran VK, Putz T, Rohde H. A randomized controlled trial for inguinal hernia repair to compare the Shouldice and the Bassini-Kirschner operation. Int Surg. Oct-Dec. 1992;77(4):235-7. [pmid: 1478801].
558 Triantafyllidis I, Chrissidis T. Laparoscopic totally extraperitoneal inguinal hernia repair: Initial experience. Surg Endosc. Mar. 2011;25:S66.
559 Tsai YC, Wu CC, Yang SS. Open versus minilaparoscopic herniorrhaphy for children: a prospective comparative trial with midterm follow-up evaluation. Surg Endosc. Jan. 2010;24(1):21-4. [pmid: 19690916].
560 Tsakayannis DE, Kiriakopoulos AC, Linos DA. Elective neurectomy during open, “tension free” inguinal hernia repair. Hernia. Feb. 2004;8(1):67-9. [pmid: 14586777].
561 Tschudi J, Wagner M, Klaiber C, et al. Controlled multicenter trial of laparoscopic transabdominal preperitoneal hernioplasty vs Shouldice herniorrhaphy. Early results. Surg Endosc. Aug. 1996;10(8):845-7. [pmid: 8694951].
562 Tucker JG, Wilson RA, Ramshaw BJ, et al. Laparoscopic herniorrhaphy: technical concerns in prevention of complications and early recurrence. Am Surg. Jan. 1995;61(1):36-9. [pmid: 7832379].
563 Turial S, Enders J, Krause K, et al. Laparoscopic inguinal herniorrhaphy in babies weighing 5 kg or less. Surg Endosc. Jan. 2011;25(1):72-8. [pmid: 20532570].
564 Twersky RS, Lebovits A, Williams C, et al. Ketorolac versus fentanyl for postoperative pain management in outpatients. Clin J Pain. Jun. 1995;11(2):127-33. [pmid: 7549168].
565 Tzovaras G, Delikoukos S, Christodoulides G, et al. The role of antibiotic prophylaxis in elective tension-free mesh inguinal hernia repair: results of a single-centre prospective randomised trial. Int J Clin Pract. Feb. 2007;61(2):236-9. [pmid: 16930145].
566 Ulman I, Demircan M, Arikan A, et al. Unilateral inguinal hernia in girls: is routine contralateral exploration justified?. J Pediatr Surg. Dec. 1995;30(12):1684-6. [pmid: 8749924].
567 Open hernia repair better than laparoscopic. J Fam Pract. Aug. 2004;53(8):608. 611.
568 Ure BM, Bax NM, van der Zee DC. Laparoscopy in infants and children: a prospective study on feasibility and the impact on routine surgery. J Pediatr Surg. Aug. 2000;35(8):1170-3. [pmid: 10945688].
569 Vale L, Ludbrook A, Grant A. Assessing the costs and consequences of laparoscopic vs open methods of groin hernia repair: a systematic review. Surg Endosc. Jun. 1. 2003;17(6):844-9. [pmid: 12632125].
570 Vale L, Grant A, McCormack K, et al. Cost-effectiveness of alternative methods of surgical repair of inguinal hernia. Int J Technol Assess Health Care. Mar. 2004;20(2):192-200. [pmid: 15209179].
571 Vallribera F, Oms LM, Gimenez M, et al. Groin hernia repair: comparison of three open techniques. Br J Surg. 1997;84(Suppl 2):85-6.
572 van den Heuvel B, Dwars BJ, Klassen DR, et al. Is surgical repair of an asymptomatic groin hernia appropriate? A review. Hernia. 2011. Feb. 5. [pmid: 21298308].
573 van den Tol MP, de Lange DC, Luijendijk RW, et al. Conventional vs open “tension-free” hernioplasty: preliminary results of a prospective multicentre randomized trial. Br J Surg. 1996;83(Suppl 2):75. [pmid: 8653372].
574 van der Pool AE, Harlaar JJ, den Hoed PT, et al. Long-term follow-up evaluation of chronic pain after endoscopic total extraperitoneal repair of primary and recurrent inguinal hernia. Surg Endosc. Jul. 2010;24(7):1707-11. [pmid: 20054573].
575 van der Zwaal P, van den Berg IR, Plaisier PW, et al. Mesh fixation using staples in Lichtenstein's inguinal hernioplasty: fewer complications and fewer recurrences. Hernia. Aug. 2008;12(4):391-4. [pmid: 18286350].
576 Van Hee R, Goverde P, Hendrickx L, et al. Laparoscopic transperitoneal versus extraperitoneal inguinal hernia repair: a prospective clinical trial. Acta Chir Belg. Jun. 1998;98(3):132-5. [pmid: 9689974].
577 van Veen RN, Wijsmuller AR, Vrijland WW, et al. Long-term follow-up of a randomized clinical trial of non-mesh versus mesh repair of primary inguinal hernia. Br J Surg. Apr. 2007;94(4):506-10. [pmid: 17279491].
578 van Veen RN, Wijsmuller AR, Vrijland WW, et al. Randomized clinical trial of mesh versus non-mesh primary inguinal hernia repair: long-term chronic pain at 10 years. Surgery. Nov. 2007;142(5):695-8. [pmid: 17981189].
579 van Veen RN, Mahabier C, Dawson I, et al. Spinal or local anesthesia in lichtenstein hernia repair: a randomized controlled trial. Ann Surg. Mar. 2008;247(3):428-33. [pmid: 18376185].
580 Varshney S, Burke D, Johnson CD. Two-layer repair of the transversalis fascia is sufficient for inguinal hernia repair. Ann R Coll Surg Engl. Jul. 1995;77(4):305-7. [pmid: 7574325].
581 Velanovich V. Laparoscopic vs open surgery: a preliminary comparison of quality-of-life outcomes. Surg Endosc. Jan. 2000;14(1):16-21. [pmid: 10653229].
582 Velanovich V, Shadduck P, Khaitan L, et al. Analysis of the SAGES Outcomes Initiative groin hernia database. Surg Endosc. Feb. 2006;20(2):191-8. [pmid: 16341567].
583 Velasco JM, Gelman C, Vallina VL. Preperitoneal bilateral inguinal herniorrhaphy evolution of a technique from conventional to laparoscopic. Surg Endosc. Feb. 1996;10(2):122-7. [pmid: 8932612].
584 Velasco JM, Vallina VL, Esposito DJ, et al. Laparoscopic herniorrhaphy in the geriatric population. Am Surg. Jul. 1998;64(7):633-7. [pmid: 9655273].
585 Vidovic D, Kirac I, Glavan E, et al. Laparoscopic totally extraperitoneal hernia repair versus open Lichtenstein hernia repair: results and complications. J Laparoendosc Adv Surg Tech A. Oct. 2007;17(5):585-90. [pmid: 17907968].
586 Vincent PJ, Singh BY, Joshi CS, et al. Recent trends in dealing with inguinal hernial sac. Med J Armed Forces India. Apr. 2003;59(2):108-10.
587 Vogt DM, Curet MJ, Pitcher DE, et al. Preliminary results of a prospective randomized trial of laparoscopic onlay versus conventional inguinal herniorrhaphy. Am J Surg. Jan. 1995;169(1):84-9. discussion 89-90. [pmid: 7818003].
588 Voyles CR, Hamilton BJ, Johnson WD, et al. Meta-analysis of laparoscopic inguinal hernia trials favors open hernia repair with preperitoneal mesh prosthesis. Am J Surg. Jul. 2002;184(1):6-10. [pmid: 12135710].
589 Vrijland WW, van den Tol MP, Luijendijk RW, et al. Randomized clinical trial of non-mesh versus mesh repair of primary inguinal hernia. Br J Surg. Mar. 2002;89(3):293-7. [pmid: 11872052].
590 Waechter FL, Sampaio JA, Pinto RD, et al. A comparison between topical and infiltrative bupivacaine and intravenous meperidine for postoperative analgesia after inguinal herniorrhaphy. Am Surg. May. 2001;67(5):447-50. [pmid: 11379646].
591 Wake BL, McCormack K, Fraser C, et al. Transabdominal pre-peritoneal (TAPP) vs totally extraperitoneal (TEP) laparoscopic techniques for inguinal hernia repair. Cochrane Database of Systematic Reviews. [internet]. Hoboken (NJ). John Wiley & Sons, Ltd. 2005;(1). 2010 Jul 2. ]. [Art. No.: CD004703]. Available:. [doi: 10.1002/14651858.CD004703.pub2]. [pmid: 15674961].
592 Wassef MR, Randazzo T, Ward W. The paravertebral nerve root block for inguinal herniorrhaphy--a comparison with the field block approach. Reg Anesth Pain Med. Sep-Oct. 1998;23(5):451-6. [pmid: 9773696].
593 Webb K. Overview of randomized trials of inguinal hernia repair-a European Union concerted action. Report of first collaborators' meeting, Nieuwegein, the Netherlands, October 16-17, 1998. EU Hernia Trialists Collaboration. Surg Endosc. Oct. 1999;13(10):1030-1. [pmid: 10526042].
594 Weiland DE, Bay RC, Del Sordi S. Choosing the best abdominal closure by meta-analysis. Am J Surg. Dec. 1998;176(6):666-70. [pmid: 9926810].
595 Welborn LG, Rice LJ, Hannallah RS, et al. Postoperative apnea in former preterm infants: prospective comparison of spinal and general anesthesia. Anesthesiology. May. 1990;72(5):838-42. [pmid: 2187377].
596 Weldon BC, Bell M, Craddock T. The effect of caudal analgesia on emergence agitation in children after sevoflurane versus halothane anesthesia. Anesth Analg. Feb. 2004;98(2):321-6. [pmid: 14742362].
597 Wennstrom I, Berggren P, Akerud L, et al. Equal results with laparoscopic and Shouldice repairs of primary inguinal hernia in men. Report from a prospective randomised study. Scand J Surg. 2004;93(1):34-6. [pmid: 15116817].
598 Weyhe D, Belyaev O, Müller C, et al. Improving outcomes in hernia repair by the use of light meshes--a comparison of different implant constructions based on a critical appraisal of the literature. World J Surg. Jan. 2007;31(1):234-44. [pmid: 17180568].
599 Weyhe D, Meurer K, Belyaev O, et al. Do various mesh placement techniques affect the outcome in totally extraperitoneal hernia repair? What is the role of the surgeon?. J Laparoendosc Adv Surg Tech A. Dec. 2007;17(6):749-57. [pmid: 18158804].
600 Wheeler KH. Laparoscopic inguinal herniorrhaphy with mesh: an 18-month experience. J Laparoendosc Surg. 1993;3(4):345-50. [pmid: 8268504].
601 Willaert W, Berrevoet F, De Bacquer D, et al. Open Preperitoneal Techniques versus Lichtenstein Repair for Inguinal Hernia. Cochrane Database of Systematic Reviews. [internet]. Hoboken (NJ). John Wiley & Sons, Ltd. 2009;(4). 2010 Jul 2. ]. [Art. No.: CD008034]. Available:. [doi: 10.1002/14651858.CD008034].
602 Williams N, Scott A. Conventional or laparoscopic inguinal hernia repair? The surgeon's choice. Ann R Coll Surg Engl. Jan. 1999;81(1):56-7. [pmid: 10325688].
603 William JM, Stoddart PA, Williams SA, et al. Post-operative recovery after inguinal herniotomy in ex-premature infants: comparison between sevoflurane and spinal anaesthesia. Br J Anaesth. Mar. 2001;86(3):366-71. [pmid: 11573526].
604 Wilson MS, Deans GT, Brough WA. Prospective trial comparing Lichtenstein with laparoscopic tension-free mesh repair of inguinal hernia. Br J Surg. Feb. 1995;82(2):274-7. [pmid: 7749710].
605 Wilson J, Younis A, Lewis-Russell J, et al. Benchmarking competency in paediatric groin surgery. Br J Med Surg Urol. Sep. 2010;3(5):215-7.
606 Winslow ER, Quasebarth M, Brunt LM. Perioperative outcomes and complications of open vs laparoscopic extraperitoneal inguinal hernia repair in a mature surgical practice. Surg Endosc. Feb. 2004;18(2):221-7. [pmid: 14625733].
607 Witkowski P, Pirski MI, Admonis W, et al. Mesh plug versus Bassini operation - follow up report of randomized prospective study. Hernia in the 21st century. Toronto. 2000:282.
608 Woods B, Neumayer L. Open repair of inguinal hernia: an evidence-based review. Surg Clin North Am. Feb. 2008;88(1):139-55. [pmid: 18267167].
609 Wulkan ML, Wiener ES, VanBalen N, et al. Laparoscopy through the open ipsilateral sac to evaluate presence of contralateral hernia. J Pediatr Surg. Aug. 1996;31(8):1174-6. discussion 1176-7. [pmid: 8863259].
610 Yamamoto S, Maeda T, Uchida Y, et al. Open tension-free mesh repair for adult inguinal hernia: eight years of experience in a community hospital. Asian J Surg. Apr. 2002;25(2):121-5. [pmid: 12376230].
611 Yerdel MA, Akin EB, Dolalan S, et al. Effect of single-dose prophylactic ampicillin and sulbactam on wound infection after tension-free inguinal hernia repair with polypropylene mesh: the randomized, double-blind, prospective trial. Ann Surg. Jan. 2001;233(1):26-33. [pmid: 11141221].
612 Zampieri N, Zuin V, Ottolenghi A, et al. Contralateral exploration for unilateral inguinal hernia in females: risk factors and surgical findings. Hernia. 2008;12(5):511-4. [pmid: 18496730].
613 Zeybek N, Tas H, Peker Y, et al. Comparison of modified darn repair and Lichtenstein repair of primary inguinal hernias. J Surg Res. May. 15. 2008;146(2):225-9. [pmid: 18314138].
614 Zhao G, Gao P, Ma B, et al. Open mesh techniques for inguinal hernia repair: a meta-analysis of randomized controlled trials. Ann Surg. Jul. 2009;250(1):35-42. [pmid: 19561484].
615 Zhu Q, Mao Z, Yu B, et al. Effects of persistent CO(2) insufflation during different laparoscopic inguinal hernioplasty: a prospective, randomized, controlled study. J Laparoendosc Adv Surg Tech A. Oct. 2009;19(5):611-4. [pmid: 19845453].
616 Zib M, Gani J. Inguinal hernia repair: where to next?. ANZ J Surg. Aug. 2002;72(8):573-9. [pmid: 12190732].
617 Zieren J, Kupper F, Paul M, et al. Inguinal hernia: obligatory indication for elective surgery? A prospective assessment of quality of life before and after plug and patch inguinal hernia repair. Langenbecks Arch Surg. Feb. 2003;387(11-12):417-20. [pmid: 12607122].
618 Zigman AF, Lynch FP, Easter DW. Laparoscopic evaluation of the asymptomatic groin in children at herniorrhaphy. Pediatr Endosurg Innov Tech. 1998;2(2):61-4.
619 Zollinger RM Jr. Classification systems for groin hernias. Surg Clin North Am. Oct. 2003;83(5):1053-63. [pmid: 14533903].
620 Zwaal P, Berg IR, Plaisier PW, et al. Mesh fixation using staples in Lichtenstein's inguinal hernioplasty: fewer complications and fewer recurrences. Hernia. Aug. 2008;12(4):391-4. [pmid: 18286350].
621 Abu-Own A, Onwudike M, Haque KA, et al. Primary inguinal hernia repair utilizing the mesh ‘plug’ technique. Ambul Surg. Jan. 2000;8(1):31-5.
622 Adamonis W, Witkowski P, Smietanski M, et al. Is there a need for a mesh plug in inguinal hernia repair? Randomized, prospective study of the use of Hertra 1 mesh compared to PerFix Plug. Hernia. Jun. 2006;10(3):223-8. [pmid: 16583149].
623 Agarwal BB, Agarwal KA, Mahajan KC. Prospective double-blind randomized controlled study comparing heavy- and lightweight polypropylene mesh in totally extraperitoneal repair of inguinal hernia: early results. Surg Endosc. Feb. 2009;23(2):242-7. [pmid: 18923870].
624 Anadol ZA, Ersoy E, Taneri F, et al. Outcome and cost comparison of laparoscopic transabdominal preperitoneal hernia repair versus Open Lichtenstein technique. J Laparoendosc Adv Surg Tech A. Jun. 2004;14(3):159-63. [pmid: 15245668].
625 Andersson B, Hallen M, Leveau P, et al. Laparoscopic extraperitoneal inguinal hernia repair versus open mesh repair: a prospective randomized controlled trial. Surgery. May. 2003;133(5):464-72. [pmid: 12773973].
626 Hallen M, Bergenfelz A, Westerdahl J. Laparoscopic extraperitoneal inguinal hernia repair versus open mesh repair: long-term follow-up of a randomized controlled trial. Surgery. Mar. 2008;143(3):313-7. [pmid: 18291251].
627 Ansaloni L, Catena F, Coccolini F, et al. Inguinal hernia repair with porcine small intestine submucosa: 3-year follow-up results of a randomized controlled trial of Lichtenstein's repair with polypropylene mesh versus Surgisis Inguinal Hernia Matrix. Am J Surg. Sep. 2009;198(3):303-12. [pmid: 19285658].
628 Ansaloni L, Catena F, D'Alessandro L. Prospective randomized, double-blind, controlled trial comparing Lichtenstein's repair of inguinal hernia with polypropylene mesh versus Surgisis gold soft tissue graft: preliminary results. Acta Biomed. Suppl 2. 2003;74:10-4. [pmid: 15055026].
629 Beets GL, Dirksen CD, Go PM, et al. Open or laparoscopic preperitoneal mesh repair for recurrent inguinal hernia? A randomized controlled trial. Surg Endosc. Apr. 1999;13(4):323-7. [pmid: 10094739].
630 Bender O, BalcI FL, Yuney E, et al. Systemic inflammatory response after Kugel versus laparoscopic groin hernia repair: a prospective randomized trial. Surg Endosc. Dec. 2009;23(12):2657-61. [pmid: 19440788].
631 Bittner R, Schmedt CG, Schwarz J, et al. Laparoscopic transperitoneal procedure for routine repair of groin hernia. Br J Surg. Aug. 2002;89(8):1062-6. [pmid: 12153636].
632 Bittner R. Laparoscopic surgery - 15 Years after clinical introduction. World J Surg. Jul. 2006;30(7):1190-203. [pmid: 16816898].
633 Leibl BJ, Schmedt CG, Schwarz J, et al. A single institution's experience with transperitoneal laparoscopic hernia repair. Am J Surg. Jun. 1998;175(6):446-52. [pmid: 9645770].
634 Wauschkuhn CA, Schwarz J, Bittner R. Laparoscopic transperitoneal inguinal hernia repair (TAPP) after radical prostatectomy: is it safe? Results of prospectively collected data of more than 200 cases. Surg Endosc. May. 2009;23(5):973-7. [pmid: 19118418].
635 Leibl BJ, Schmedt CG, Kraft K, et al. Recurrence after endoscopic transperitoneal hernia repair (TAPP): causes, reparative techniques, and results of the reoperation. J Am Coll Surg. Jun. 2000;190(6):651-5. [pmid: 10872999].
636 Bittner R, Leibl BJ, Kraft B, et al. One-year results of a prospective, randomised clinical trial comparing four meshes in laparoscopic inguinal hernia repair (TAPP). Hernia. Oct. 2011;15(5):503-10. [pmid: 21461904].
637 Bittner R, Schmedt CG, Leibl BJ, et al. Early postoperative and one year results of a randomized controlled trial comparing the impact of extralight titanized polypropylene mesh and traditional heavyweight polypropylene mesh on pain and seroma production in laparoscopic hernia repair (TAPP). World J Surg. Aug. 2011;35(8):1791-7. [pmid: 21607821].
638 Bobrzynski A, Budzynski A, Biesiada Z, et al. Experience--the key factor in successful laparoscopic total extraperitoneal and transabdominal preperitoneal hernia repair. Hernia. Jun. 2001;5(2):80-3. [pmid: 11505653].
639 Boldo E, Armelles A, Perez de Lucia G, et al. Pain after laparascopic bilateral hernioplasty: early results of a prospective randomized double-blind study comparing fibrin versus st. Surg Endosc. May. 2008;22(5):1206-9. [pmid: 17943371].
640 Bostanci BE, Tetik C, Ozer S, et al. Posterior approaches in groin hernia repair with prosthesis: open or closed. Acta Chir Belg. Dec. 1998;98(6):241-4. [pmid: 9922810].
641 Bringman S, Ramel S, Heikkinen TJ, et al. Tension-free inguinal hernia repair: TEP versus mesh-plug versus Lichtenstein: a prospective randomized controlled trial. Ann Surg. Jan. 2003;237(1):142-7. [pmid: 12496542].
642 Bringman S, Heikkinen TJ, Wollert S, et al. Early results of a single-blinded, randomized, controlled, Internet-based multicenter trial comparing Prolene and Vypro II mesh in Lichtenstein hernioplasty. Hernia. May. 2004;8(2):127-34. [pmid: 14648244].
643 Bringman S, Wollert S, Osterberg J, et al. One year results of a randomised controlled multi-centre study comparing Prolene and Vypro II-mesh in Lichtenstein hernioplasty. Hernia. Oct. 2005;9(3):223-7. [pmid: 16450078].
644 Bringman S, Wollert S, Osterberg J, et al. Three-year results of a randomized clinical trial of lightweight or standard polypropylene mesh in Lichtenstein repair of primary inguinal hernia. Br J Surg. Sep. 2006;93(9):1056-9. [pmid: 16862613].
645 Bringman S, Wollert S, Osterberg J, et al. Early results of a randomized multicenter trial comparing Prolene and VyproII mesh in bilateral endoscopic extraperitoneal hernioplasty (TEP). Surg Endosc. Apr. 2005;19(4):536-40. [pmid: 15759178].
646 Bueno J, Serralta A, Planells M, et al. Inguinodynia after two inguinal herniorrhaphy methods. Surg Laparosc Endosc Percutan Tech. Aug. 2004;14(4):210-4. [pmid: 15472550].
647 Butler RE, Burke R, Schneider JJ, et al. The economic impact of laparoscopic inguinal hernia repair: results of a double-blinded, prospective, randomized trial. Surg Endosc. Mar. 2007;21(3):387-90. [pmid: 17235721].
648 Butters M, Redecke J, Koninger J. Long-term results of a randomized clinical trial of Shouldice, Lichtenstein and transabdominal preperitoneal hernia repairs. Br J Surg. May. 2007;94(5):562-5. [pmid: 17443855].
649 Koninger JS, Oster M, Butters M. Management of inguinal hernia--a comparison of current methods. Chirurg. Dec. 1998;69(12):1340-4. [pmid: 10023558].
650 Canonico S, Sciaudone G, Pacifico F, et al. Inguinal hernia repair in patients with coagulation problems: prevention of postoperative bleeding with human fibrin glue. Surgery. Mar. 1999;125(3):315-7. [pmid: 10076616].
651 Champault GG, Rizk N, Catheline JM, et al. Inguinal hernia repair: totally preperitoneal laparoscopic approach versus Stoppa operation: randomized trial of 100 cases. Surg Laparosc Endosc. Dec. 1997;7(6):445-50. [pmid: 9438623].
652 Occelli G, Barrat C, Catheline JM, et al. Laparoscopic treatment of inguinal hernias: prospective evaluation of 757 cases treated by a totally extraperitoneal route. Hernia. Jun. 2000;4(2):81-4.
653 Champault G, Rizk N, Catheline JM, et al. Inguinal hernia. Pre-peritoneal laparoscopic surgery vs. the Stoppa procedure. A prospective randomized trial: 100 cases. J Chir (Paris). Sep. 1996;133(6):274-80. [pmid: 8949271].
654 Hernies de l'aine. Resultats a 4 ans deux etudes prospectives randomisees comparant les operations de Shouldice et de Stoppa a l'abord laparoscopique totalement pre-peritoneal (461 patients). Ann Chir. 1998;52:132-6. [pmid: 9752429].
655 Barrat C, Seriser F, Arnoud R, et al. Inguinal hernia repair with beta glucan-coated mesh: prospective multicenter study (115 cases)--preliminary results. Hernia. Feb. 2004;8(1):33-8. [pmid: 13680304].
656 Champault G, Barrat C. Inguinal hernia repair with beta glucan-coated mesh: results at two-year follow up. Hernia. May. 2005;9(2):125-30. [pmid: 15602625].
657 Chan KL, Hui WC, Tam PK. Prospective randomized single-center, single-blind comparison of laparoscopic vs open repair of pediatric inguinal hernia. Surg Endosc. Jul. 2005;19(7):927-32. [pmid: 15920685].
658 Chauhan A, Tiwari S, Gupta A. Study of efficacy of bilayer mesh device versus conventional polypropelene hernia system in inguinal hernia repair: early results. World J Surg. Jun. 2007;31(6):1356-9. discussion 1360-1. [pmid: 17437156].
659 Cheah WK, So JB, Lomanto D. Endoscopic extraperitoneal inguinal hernia repair: a series of 182 repairs. Singapore Med J. Jun. 2004;45(6):267-70. [pmid: 15181520].
660 Chowbey PK, Garg N, Sharma A, et al. Prospective randomized clinical trial comparing lightweight mesh and heavyweight polypropylene mesh in endoscopic totally extraperitoneal groin hernia repair. Surg Endosc. Dec. 2010;24(12):3073-9. [pmid: 20490567].
661 Chui LB, Ng WT, Sze YS, et al. Prospective, randomized, controlled trial comparing lightweight versus heavyweight mesh in chronic pain incidence after TEP repair of bilateral inguinal hernia. Surg Endosc. 2010. Apr. 8. [pmid: 20376498].
662 Colak T, Akca T, Kanik A, et al. Randomized clinical trial comparing laparoscopic totally extraperitoneal approach with open mesh repair in inguinal hernia. Surg Laparosc Endosc Percutan Tech. Jun. 2003;13(3):191-5. [pmid: 12819504].
663 Polish Hernia Study Group, Smietanski M. Randomized clinical trial comparing a polypropylene with a poliglecaprone and polypropylene composite mesh for inguinal hernioplasty. Br J Surg. Dec. 2008;95(12):1462-8. [pmid: 18991255].
664 Coskun F, Ozmen MM, Moran M, et al. New technique for inguinal hernia repair. Hernia. Mar. 2005;9(1):32-6. [pmid: 15611838].
665 Dalenback J, Andersson C, Anesten B, et al. Prolene Hernia System, Lichtenstein mesh and plug-and-patch for primary inguinal hernia repair: 3-year outcome of a prospective randomised controlled trial. The BOOP study: [TRUNC]. Hernia. Apr. 2009;13(2):121-9. discussion 231. [pmid: 19015933].
666 Davies NM, Dunn DC, Appleton B, et al. Experience with 300 laparoscopic inguinal hernia repairs with up to 3 years follow-up. Ann R Coll Surg Engl. Nov. 1995;77(6):409-12. [pmid: 8540657].
667 Dunn DC, Wijesinghe LD, Pollard SG, et al. Post-operative rehabilitation following laparoscopic inguinal hernia repair. Minim Invasive Ther. 1994;3(3):159-62.
668 DeBord JR, Bauer JJ, Grischkan DM, et al. Short-term study on the safety of antimicrobial-agent-impregnated ePTFE patches for hernia repair. Hernia. Dec. 1999;3(4):189-93.
669 Dedemadi G, Sgourakis G, Karaliotas C, et al. Comparison of laparoscopic and open tension-free repair of recurrent inguinal hernias: a prospective randomized study. Surg Endosc. Jul. 2006;20(7):1099-104. [pmid: 16763926].
670 Di Vita G, Patti R, Barrera T, et al. Impact of heavy polypropylene mesh and composite light polypropylene and polyglactin 910 on the inflammatory response. Surg Innov. Sep. 2010;17(3):229-35. [pmid: 20798094].
671 Dirksen CD, Beets GL, Go PM, et al. Bassini repair compared with laparoscopic repair for primary inguinal hernia: a randomised controlled trial. Eur J Surg. Jun. 1998;164(6):439-47. [pmid: 9696445].
672 Dirksen CD, Ament AJ, Adang EM, et al. Cost-effectiveness of open versus laparoscopic repair for primary inguinal hernia. Int J Technol Assess Health Care. Summer. 1998;14(3):472-83. [pmid: 9780534].
673 Dogru O, Girgin M, Bulbuller N, et al. Comparison of Kugel and Lichtenstein operations for inguinal hernia repair: results of a prospective randomized study. World J Surg. Mar. 2006;30(3):346-50. [pmid: 16479339].
674 Douek M, Smith G, Oshowo A, et al. Prospective randomised controlled trial of laparoscopic versus open inguinal hernia mesh repair: five year follow up. BMJ. May. 10. 2003;326(7397):1012-3. [pmid: 12742923].
675 Wellwood J, Sculpher MJ, Stoker D, et al. Randomised controlled trial of laparoscopic versus open mesh repair for inguinal hernia: outcome and cost. BMJ. Jul. 11. 1998;317(7151):103-10. [pmid: 9657784].
676 Douglas JM, Young WN, Jones DB. Lichtenstein inguinal herniorrhaphy using sutures versus tacks. Hernia. Sep. 2002;6(3):99-101. [pmid: 12209296].
677 Dulucq JL, Wintringer P, Mahajna A. Laparoscopic totally extraperitoneal inguinal hernia repair: lessons learned from 3,100 hernia repairs over 15 years. Surg Endosc. Mar. 2009;23(3):482-6. [pmid: 18810548].
678 Edwards CC 2nd, Bailey RW. Laparoscopic hernia repair: the learning curve. Surg Laparosc Endosc Percutan Tech. Jun. 2000;10(3):149-53. [pmid: 10872976].
679 Eklund A, Rudberg C, Smedberg S, et al. Short-term results of a randomized clinical trial comparing Lichtenstein open repair with totally extraperitoneal laparoscopic inguinal hernia repair. Br J Surg. Sep. 2006;93(9):1060-8. [pmid: 16862612].
680 Eklund A, Carlsson P, Rosenblad A, et al. Long-term cost-minimization analysis comparing laparoscopic with open (Lichtenstein) inguinal hernia repair. Br J Surg. May. 2010;97(5):765-71. [pmid: 20186996].
681 Eklund A, Montgomery A, Bergkvist L, et al. Chronic pain 5 years after randomized comparison of laparoscopic and Lichtenstein inguinal hernia repair. Br J Surg. Apr. 2010;97(4):600-8. [pmid: 20186889].
682 Eklund AS, Montgomery AK, Rasmussen IC, et al. Low recurrence rate after laparoscopic (TEP) and open (Lichtenstein) inguinal hernia repair: a randomized, multicenter trial with 5-year follow-up. Ann Surg. Jan. 2009;249(1):33-8. [pmid: 19106673].
683 Eklund A, Rudberg C, Leijonmarck CE, et al. Recurrent inguinal hernia: randomized multicenter trial comparing laparoscopic and Lichtenstein repair. Surg Endosc. Apr. 2007;21(4):634-40. [pmid: 17364153].
684 Feliu-Pala X, Martin-Gomez M, Morales-Conde S, et al. The impact of the surgeon's experience on the results of laparoscopic hernia repair. Surg Endosc. Dec. 2001;15(12):1467-70. [pmid: 11965467].
685 Felix E, Scott S, Crafton B, et al. Causes of recurrence after laparoscopic hernioplasty. A multicenter study. Surg Endosc. Mar. 1998;12(3):226-31. [pmid: 9502701].
686 Ferzli G, Kiel T. Evolving techniques in endoscopic extraperitoneal herniorrhaphy. Surg Endosc. Aug. 1995;9(8):928-30. [pmid: 8525452].
687 Ferzli GS, Frezza EE, Pecoraro AM Jr, et al. Prospective randomized study of stapled versus unstapled mesh in a laparoscopic preperitoneal inguinal hernia repair. J Am Coll Surg. May. 1999;188(5):461-5. [pmid: 10235572].
688 Fitzgibbons RJ Jr, Giobbie-Hurder A, Gibbs JO, et al. Watchful waiting vs repair of inguinal hernia in minimally symptomatic men: a randomized clinical trial. JAMA. Jan. 18. 2006;295(3):285-92. [pmid: 16418463].
689 Stroupe KT, Manheim LM, Luo P, et al. Tension-free repair versus watchful waiting for men with asymptomatic or minimally symptomatic inguinal hernias: a cost-effectiveness analysis. J Am Coll Surg. Oct. 2006;203(4):458-68. [pmid: 17000388].
690 O'Dwyer PJ, Chung L. Watchful waiting was as safe as surgical repair for minimally symptomatic inguinal hernias: commentary. Evid Based Med. Jun. 2006;11(3):73. [pmid: 17213095].
691 Watchful waiting acceptable option for inguinal hernia. J Fam Pract. Apr. 2006;55(4):282.
692 Gibbs JO, Giobbie-Hurder A, Edelman P, et al. Does delay of hernia repair in minimally symptomatic men burden the patient's family?. J Am Coll Surg. Sep. 2007;205(3):409-12. [pmid: 17765156].
693 Fitzgibbons RJ, Jonasson O, Gibbs J, et al. The development of a clinical trial to determine if watchful waiting is an acceptable alternative to routine herniorrhaphy for patients with minimal or no hernia symptoms. J Am Coll Surg. May. 2003;196(5):737-42. [pmid: 12742207].
694 Sarosi GA, Wei Y, Gibbs JO, et al. A Clinician's guide to patient selection for watchful waiting management of inguinal hernia. Ann Surg. Mar. 2011;253(3):605-10. [pmid: 21239979].
695 Fortelny RH, Petter-Puchner AH, May C, et al. The impact of atraumatic fibrin sealant vs. staple mesh fixation in TAPP hernia repair on chronic pain and quality of life: results of a randomized controlled study. Surg Endosc. 2011. Aug. 19. [pmid: 21853390].
696 Freudenberg S, Sano D, Ouangre E, et al. Commercial mesh versus Nylon mosquito net for hernia repair. A randomized double-blind study in Burkina Faso. World J Surg. Oct. 2006;30(10):1784-9. dicussion 1790. [pmid: 16983472].
697 Frey DM, Wildisen A, Hamel CT, et al. Randomized clinical trial of Lichtenstein's operation versus mesh plug for inguinal hernia repair. Br J Surg. Jan. 2007;94(1):36-41. [pmid: 17094166].
698 Garg P, Nair S, Menon GR, et al. Mesh fixation compared to non-fixation in total extraperitoneal inguinal hernia repair: a randomized controlled trial in a rural center in India. Surg Endosc. Mar. 2011;25:3300-6. [pmid: 21533969].
699 Geis WP, Crafton WB, Novak MJ, et al. Laparoscopic herniorrhaphy: results and technical aspects in 450 consecutive procedures. Surgery. Oct. 1993;114(4):765-72. discussion 772-4. [pmid: 8211692].
700 Gokalp A, Inal M, Maralcan G, et al. A prospective randomized study of Lichtenstein open tension-free versus laparoscopic totally extraperitoneal techniques for inguinal hernia repair. Acta Chir Belg. Oct. 2003;103(5):502-6. [pmid: 14653037].
701 Gong K, Zhang N, Lu Y, et al. Comparison of the open tension-free mesh-plug, transabdominal preperitoneal (TAPP), and totally extraperitoneal (TEP) laparoscopic techniques for primary unilateral inguinal hernia repair: a prospective randomized controlled trial. Surg Endosc. Jan. 2011;25(1):234-9. [pmid: 20552368].
702 Gunal O, Ozer S, Gurleyik E, et al. Does the approach to the groin make a difference in hernia repair?. Hernia. Oct. 2007;11(5):429-34. [pmid: 17610024].
703 Gundre NP, Iyer SP, Subramaniyan P. Prospective randomized controlled study using polyethylene mesh for inguinal hernia meshplasty as a safe and cost-effective alternative to polypropylene mesh. Updates Surg. 2011. Aug. 18. [pmid: 21850553].
704 Hamza Y, Gabr E, Hammadi H, et al. Four-arm randomized trial comparing laparoscopic and open hernia repairs. Int J Surg. 2010;8(1):25-8. [pmid: 19796714].
705 Heikkinen T, Haukipuro K, Leppala J, et al. Total costs of laparoscopic and lichtenstein inguinal hernia repairs: a randomized prospective study. Surg Laparosc Endosc. Feb. 1997;7(1):1-5. [pmid: 9116938].
706 Heikkinen T, Bringman S, Ohtonen P, et al. Five-year outcome of laparoscopic and Lichtenstein hernioplasties. Surg Endosc. Mar. 2004;18(3):518-22. [pmid: 14735339].
707 Heikkinen TJ, Haukipuro K, Koivukangas P, et al. A prospective randomized outcome and cost comparison of totally extraperitoneal endoscopic hernioplasty versus Lichtenstein hernia operation among employed patients. Surg Laparosc Endosc. Oct. 1998;8(5):338-44. [pmid: 9799140].
708 Heikkinen TJ, Haukipuro K, Hulkko A. A cost and outcome comparison between laparoscopic and Lichtenstein hernia operations in a day-case unit. A randomized prospective study. Surg Endosc. Oct. 1998;12(10):1199-203. [pmid: 9745056].
709 Heikkinen T, Wollert S, Osterberg J, et al. Early results of a randomised trial comparing Prolene and VyproII-mesh in endoscopic extraperitoneal inguinal hernia repair (TEP) of recurrent unilateral hernias. Hernia. Mar. 2006;10(1):34-40. [pmid: 16088358].
710 Helbling C, Schlumpf R. Sutureless Lichtenstein: first results of a prospective randomised clinical trial. Hernia. Jun. 2003;7(2):80-4. [pmid: 12820029].
711 Kim-Fuchs C, Angst E, Vorburger S, et al. Prospective randomized trial comparing sutured with sutureless mesh fixation for Lichtenstein hernia repair: long-term results. Hernia. 2011. Jul. 26. [pmid: 21789654].
712 Johansson B, Hallerback B, Glise H, et al. Laparoscopic mesh versus open preperitoneal mesh versus conventional technique for inguinal hernia repair: a randomized multicenter trial (SCUR Hernia Repair Study). Ann Surg. Aug. 1999;230(2):225-31. [pmid: 10450737].
713 Johansson B, Hallerback B, Gilse H, et al. Laparscopic mesh repair vs open repair w/wo mesh graft for inguinal hernia (SCUR groin hernia repair study). Preliminary results. [abstract S03]. Surg Endosc. 1997;11:170.
714 Kanakala V, Bawa S, Gallagher P, et al. Outcome of patients in laparoscopic training courses compared to standard patients. Surgeon. Jun. 2010;8(3):132-5. [pmid: 20400021].
715 Kapiris SA, Brough WA, Royston CM, et al. Laparoscopic transabdominal preperitoneal (TAPP) hernia repair. A 7-year two-center experience in 3017patients. Surg Endosc. Sep. 2001;15(9):972-5. [pmid: 11605111].
716 Kapischke M, Schulze H, Caliebe A. Self-fixating mesh for the Lichtenstein procedure--a prestudy. Langenbecks Arch Surg. Apr. 2010;395(4):317-22. [pmid: 20174819].
717 Khan N, Bangash A, Sadiq M, et al. Polyglactine/polypropylene mesh vs. propylene mesh: is there a need for newer prosthesis in inguinal hernia?. Saudi J Gastroenterol. Jan-Mar. 2010;16(1):8-13. [pmid: 20065567].
718 Khoury N. A randomized prospective controlled trial of laparoscopic extraperitoneal hernia repair and mesh-plug hernioplasty: a study of 315 cases. J Laparoendosc Adv Surg Tech A. Dec. 1998;8(6):367-72. [pmid: 9916589].
719 Kieturakis MJ, Nguyen DT, Vargas H, et al. Balloon dissection facilitated laparoscopic extraperitoneal hernioplasty. Am J Surg. Dec. 1994;168(6):603-7. discussion 607-8. [pmid: 7978004].
720 Kingsnorth AN, Porter CS, Bennett DH, et al. Lichtenstein patch or Perfix plug-and-patch in inguinal hernia: a prospective double-blind randomized controlled trial of short-term outcome. Surgery. Mar. 2000;127(3):276-83. [pmid: 10715982].
721 Kingsnorth AN, Wright D, Porter CS, et al. Prolene Hernia System compared with Lichtenstein patch: a randomised double blind study of short-term and medium-term outcomes in primary inguinal hernia repair. Hernia. Sep. 2002;6(3):113-9. [pmid: 12209299].
722 Koc M, Aslar AK, Yoldas O, et al. Comparison of quality-of-life outcomes of Stoppa vs bilateral Lichtenstein procedure. Hernia. Feb. 2004;8(1):53-5. [pmid: 14505239].
723 Koch CA, Greenlee SM, Larson DR, et al. Randomized prospective study of totally extraperitoneal inguinal hernia repair: fixation versus no fixation of mesh. JSLS. Oct-Dec. 2006;10(4):457-60. [pmid: 17575757].
724 Koch A, Bringman S, Myrelid P, et al. Randomized clinical trial of groin hernia repair with titanium-coated lightweight mesh compared with standard polypropylene mesh. Br J Surg. Oct. 2008;95(10):1226-31. [pmid: 18763243].
725 Koivusalo AI, Korpela R, Wirtavuori K, et al. A single-blinded, randomized comparison of laparoscopic versus open hernia repair in children. Pediatrics. Jan. 2009;123(1):332-7. [pmid: 19117900].
726 Koninger J, Redecke J, Butters M. Chronic pain after hernia repair: a randomized trial comparing Shouldice, Lichtenstein and TAPP. Langenbecks Arch Surg. Oct. 2004;389(5):361-5. [pmid: 15243743].
727 Kouhia ST, Huttunen R, Silvasti SO, et al. Lichtenstein hernioplasty versus totally extraperitoneal laparoscopic hernioplasty in treatment of recurrent inguinal hernia--a prospective randomized trial. Ann Surg. Mar. 2009;249(3):384-7. [pmid: 19247022].
728 Krishna A, Misra MC, Bansal VK, et al. Laparoscopic inguinal hernia repair: transabdominal preperitoneal (TAPP) versus totally extraperitoneal (TEP) approach: a prospective randomized controlled trial. Surg Endosc. 2011. Sep. 30. [pmid: 21959688].
729 Lal P, Kajla RK, Chander J, et al. Randomized controlled study of laparoscopic total extraperitoneal versus open Lichtenstein inguinal hernia repair. Surg Endosc. Jun. 2003;17(6):850-6. [pmid: 12658428].
730 Lal P, Kajla RK, Chander J, et al. Laparoscopic total extraperitoneal (TEP) inguinal hernia repair: overcoming the learning curve. Surg Endosc. Apr. 2004;18(4):642-5. [pmid: 15026913].
731 Lamb AD, Robson AJ, Nixon SJ. Recurrence after totally extraperitoneal laparoscopic repair: implications for operative technique and surgical training. Surgeon. Oct. 2006;4(5):299-307. [pmid: 17009549].
732 Robson AJ, Wallace CG, Sharma AK, et al. Effects of training and supervision on recurrence rate after inguinal hernia repair. Br J Surg. Jun. 2004;91(6):774-7. [pmid: 15164450].
733 Langenbach MR, Schmidt J, Zirngibl H. Comparison of biomaterials in the early postoperative period. Surg Endosc. Jul. 2003;17(7):1105-9. [pmid: 12728375].
734 Langenbach MR, Schmidt J, Zirngibl H. Comparison of biomaterials: three meshes and TAPP for inguinal hernia. Surg Endosc. Oct. 2006;20(10):1511-7. [pmid: 16915511].
735 Langenbach MR, Schmidt J, Ubrig B, et al. Sixty-month follow-up after endoscopic inguinal hernia repair with three types of mesh: a prospective randomized trial. Surg Endosc. Aug. 2008;22(8):1790-7. [pmid: 18398650].
736 Langeveld HR, van't Riet M, Weidema WF, et al. Total extraperitoneal inguinal hernia repair compared with Lichtenstein (the LEVEL-Trial): a randomized controlled trial. Ann Surg. May. 2010;251(5):819-24. [pmid: 20395851].
737 Lau H, Patil NG, Yuen WK, et al. Learning curve for unilateral endoscopic totally extraperitoneal (TEP) inguinal hernioplasty. Surg Endosc. Dec. 2002;16(12):1724-8. [pmid: 12098025].
738 Lau H. Fibrin sealant versus mechanical stapling for mesh fixation during endoscopic extraperitoneal inguinal hernioplasty: a randomized prospective trial. Ann Surg. Nov. 2005;242(5):670-5. [pmid: 16244540].
739 Lau H, Patil NG, Yuen WK. Day-case endoscopic totally extraperitoneal inguinal hernioplasty versus open Lichtenstein hernioplasty for unilateral primary inguinal hernia in males: a randomized trial. Surg Endosc. Jan. 2006;20(1):76-81. [pmid: 16247575].
740 Leibl BJ, Kraft B, Redecke JD, et al. Are postoperative complaints and complications influenced by different techniques in fashioning and fixing the mesh in transperitoneal laparoscopic hernioplasty? Results of a prospective randomized trial. World J Surg. Dec. 2002;26(12):1481-4. [pmid: 12297933].
741 Liem MS, van der Graaf Y, van Steensel CJ, et al. Comparison of conventional anterior surgery and laparoscopic surgery for inguinal-hernia repair. N Engl J Med. May. 29. 1997;336(22):1541-7. [pmid: 9164809].
742 Liem MS, van Duyn EB, van der Graaf Y, et al. Recurrences after conventional anterior and laparoscopic inguinal hernia repair: a randomized comparison. Ann Surg. Jan. 2003;237(1):136-41. [pmid: 12496541].
743 Liem MS, Halsema JA, van der Graaf Y, et al. Cost-effectiveness of extraperitoneal laparoscopic inguinal hernia repair: a randomized comparison with conventional herniorrhaphy. Coala trial group. Ann Surg. Dec. 1997;226(6):668-75. discussion 675-6. [pmid: 9409566].
744 Liem MS, van Steensel CJ, Boelhouwer RU, et al. The learning curve for totally extraperitoneal laparoscopic inguinal hernia repair. Am J Surg. Feb. 1996;171(2):281-5. [pmid: 8619468].
745 Liem MS, van der Graaf Y, van Steensel CJ, et al. Faster recovery and fewer recurrences after laparoscopic than after conventional inguinal hernia surgery; a prospective randomized study. Nederlands Tijdschrift Voor Geneeskunde. 1997;141(29):1430-6.
746 Liem MS, van der Graaf Y, Zwart RC, et al. A randomised comparison of physical performance following laparoscopic and open inguinal hernia repair. Br J Surg. 1997;84:64-7. [pmid: 9043455].
747 Wright D, O'Dwyer PJ. The learning curve for laparoscopic hernia repair. Semin Laparosc Surg. Dec. 1998;5(4):227-32. [pmid: 9854130].
748 Lovisetto F, Zonta S, Rota E, et al. Laparoscopic transabdominal preperitoneal (TAPP) hernia repair: surgical phases and complications. Surg Endosc. Apr. 2007;21(4):646-52. [pmid: 17103276].
749 Lovisetto F, Zonta S, Rota E, et al. Use of human fibrin glue (Tissucol) versus staples for mesh fixation in laparoscopic transabdominal preperitoneal hernioplasty: a prospective, randomized study. Ann Surg. Feb. 2007;245(2):222-31. [pmid: 17245175].
750 Mesci A, Korkmaz B, Dinckan A, et al. Digital evaluation of the muscle functions of the lower extremities among inguinal hernia patients treated using three different surgical techniques: a prospective randomized study. Surg Today. 2011. Nov. 3. [pmid: 22045231].
751 Mills IW, McDermott IM, Ratliff DA. Prospective randomized controlled trial to compare skin staples and polypropylene for securing the mesh in inguinal hernia repair. Br J Surg. Jun. 1998;85(6):790-2. [pmid: 9667709].
752 Moreno-Egea A, Torralba Martinez JA, Morales Cuenca G, et al. Randomized clinical trial of fixation vs nonfixation of mesh in total extraperitoneal inguinal hernioplasty. Arch Surg. Dec. 2004;139(12):1376-9. [pmid: 15611465].
753 Laparoscopic versus open repair of groin hernia: a randomised comparison. The MRC Laparoscopic Groin Hernia Trial Group. Lancet. Jul. 17. 1999;354(9174):185-90. [pmid: 10421299].
754 Wright D, Paterson C, Scott N, et al. Five-year follow-up of patients undergoing laparoscopic or open groin hernia repair: a randomized controlled trial. Ann Surg. Mar. 2002;235(3):333-7. [pmid: 11882754].
755 Medical Research Council Laparoscopic Groin Hernia Trial Group. Cost-utility analysis of open versus laparoscopic groin hernia repair: results from a multicentre randomized clinical trial. Br J Surg. May. 2001;88(5):653-61. [pmid: 11350435].
756 Wright DM, Hall MG, Paterson CR, et al. A randomized comparison of driver reaction time after open and endoscopic tension-free inguinal hernia repair. Surg Endosc. Apr. 1999;13(4):332-4. [pmid: 10094741].
757 Wright DM, Kennedy A, Baxter JN, et al. Early outcome after open versus extraperitoneal endoscopic tension-free hernioplasty: a randomized clinical trial. Surgery. May. 1996;119(5):552-7. [pmid: 8619212].
758 Scott NW, Grant AM, Ross SJ, et al. Patient-assessed outcome up to three months in a randomized controlled trial comparing laparoscopic with open groin hernia repair. Hernia. 2000;4:73-9.
759 Grant AM, Scott NW, O'Dwyer PJ, et al. Five-year follow-up of a randomized trial to assess pain and numbness after laparoscopic or open repair of groin hernia. Br J Surg. Dec. 2004;91(12):1570-4. [pmid: 15515112].
760 Kumar S, Nixon SJ, MacIntyre IM. Laparoscopic or Lichtenstein repair for recurrent inguinal hernia: one unit's experience. J R Coll Surg Edinb. Oct. 1999;44(5):301-2. [pmid: 10550952].
761 Muldoon RL, Marchant K, Johnson DD, et al. Lichtenstein vs anterior preperitoneal prosthetic mesh placement in open inguinal hernia repair: a prospective, randomized trial. Hernia. May. 2004;8(2):98-103. [pmid: 14625698].
762 Neumayer L, Giobbie-Hurder A, Jonasson O, et al. Open mesh versus laparoscopic mesh repair of inguinal hernia. N Engl J Med. Apr. 29. 2004;350(18):1819-27. [pmid: 15107485].
763 Hynes DM, Stroupe KT, Luo P, et al. Cost effectiveness of laparoscopic versus open mesh hernia operation: results of a Department of Veterans Affairs randomized clinical trial. J Am Coll Surg. Oct. 2006;203(4):447-57. [pmid: 17000387].
764 Matthews RD, Anthony T, Kim LT, et al. Factors associated with postoperative complications and hernia recurrence for patients undergoing inguinal hernia repair: a report from the VA Cooperative Hernia Study Group. Am J Surg. Nov. 2007;194(5):611-7. [pmid: 17936422].
765 Kaafarani HM, Itani KM, Giobbie-Hurder A, et al. Does surgeon frustration and satisfaction with the operation predict outcomes of open or laparoscopic inguinal hernia repair?. J Am Coll Surg. May. 2005;200(5):677-83. [pmid: 15848357].
766 Neumayer L, Jonasson O, Fitzgibbons R, et al. Tension-free inguinal hernia repair: the design of a trial to compare open and laparoscopic surgical techniques. J Am Coll Surg. May. 2003;196(5):743-52. [pmid: 12742208].
767 Neumayer LA, Gawande AA, Wang J, et al. Proficiency of surgeons in inguinal hernia repair: effect of experience and age. Ann Surg. Sep. 2005;242(3):344-8. discussion 348-52. [pmid: 16135920].
768 Wilkiemeyer M, Pappas TN, Giobbie-Hurder A, et al. Does resident post graduate year influence the outcomes of inguinal hernia repair?. Ann Surg. Jun. 2005;241(6):879-82. discussion 882-4. [pmid: 15912037].
769 Nienhuijs SW, van Oort I, Keemers-Gels ME, et al. Randomized trial comparing the Prolene Hernia System, mesh plug repair and Lichtenstein method for open inguinal hernia repair. Br J Surg. Jan. 2005;92(1):33-8. [pmid: 15593293].
770 Nienhuijs SW, Boelens OB, Strobbe LJ. Pain after anterior mesh hernia repair. J Am Coll Surg. Jun. 2005;200(6):885-9. [pmid: 15922201].
771 Nienhuijs S, Kortmann B, Boerma M, et al. Preferred mesh-based inguinal hernia repair in a teaching setting: results of a randomized study. Arch Surg. Oct. 2004;139(10):1097-100. [pmid: 15492151].
772 Nienhuijs S, Staal E, Keemers-Gels M, et al. Pain after open preperitoneal repair versus Lichtenstein repair: a randomized trial. World J Surg. Sep. 2007;31(9):1751-7. discussion 1758-9. [pmid: 17510766].
773 Nikkolo C, Lepner U, Murruste M, et al. Randomised clinical trial comparing lightweight mesh with heavyweight mesh for inguinal hernioplasty. Hernia. Jun. 2010;14(3):253-8. [pmid: 20091327].
774 Nowobilski W, Dobosz M, Wojciechowicz T, et al. Lichtenstein inguinal hernioplasty using butyl-2-cyanoacrylate versus sutures. Preliminary experience of a prospective randomized trial. Eur Surg Res. Nov-Dec. 2004;36(6):367-70. [pmid: 15591746].
775 O'Dwyer PJ, Kingsnorth AN, Molloy RG, et al. Randomized clinical trial assessing impact of a lightweight or heavyweight mesh on chronic pain after inguinal hernia repair. Br J Surg. Feb. 2005;92(2):166-70. [pmid: 15584057].
776 O'Dwyer PJ, Norrie J, Alani A, et al. Observation or operation for patients with an asymptomatic inguinal hernia: a randomized clinical trial. Ann Surg. Aug. 2006;244(2):167-73. [pmid: 16858177].
777 Chung L, Norrie J, O'Dwyer PJ. Long-term follow-up of patients with a painless inguinal hernia from a randomized clinical trial. Br J Surg. Apr. 2011;98(4):596-9. [pmid: 21656724].
778 Olmi S, Scaini A, Erba L, et al. Quantification of pain in laparoscopic transabdominal preperitoneal (TAPP) inguinal hernioplasty identifies marked differences between prosthesis fixation systems. Surgery. Jul. 2007;142(1):40-6. [pmid: 17629999].
779 Ozmen M, Zulfikaroglu B, Ozalp N, et al. Femoral vessel blood flow dynamics following totally extraperitoneal vs Stoppa procedure in bilateral inguinal hernias. Am J Surg. Jun. 2010;199(6):741-5. [pmid: 20609719].
780 Paajanen H. Do absorbable mesh sutures cause less chronic pain than nonabsorbable sutures after Lichtenstein inguinal herniorraphy. Hernia. Mar. 2002;6(1):26-8. [pmid: 12090577].
781 Paajanen H. A single-surgeon randomized trial comparing three composite meshes on chronic pain after Lichtenstein hernia repair in local anesthesia. Hernia. Aug. 2007;11(4):335-9. [pmid: 17492341].
782 Paajanen H, Kossi J, Silvasti S, et al. Randomized clinical trial of tissue glue versus absorbable sutures for mesh fixation in local anaesthetic Lichtenstein hernia repair. Br J Surg. Sep. 2011;98(9):1245-51. [pmid: 21710480].
783 Paganini AM, Lezoche E, Carle F, et al. A randomized, controlled, clinical study of laparoscopic vs open tension-free inguinal hernia repair. Surg Endosc. Jul. 1998;12(7):979-86. [pmid: 9632874].
784 Paradowski T, Olejarz A, Kontny T, et al. Polypropylene vs. ePTFE vs. WN mesh for Lichtenstein inguinal hernia repair - A prospective randomized, double blind pilotstudy of one-year follow-up. Wideochir I Inne Tech Maloinwazyjne. 2009;4(1):6-9.
785 Parshad R, Kumar R, Hazrah P, et al. A randomized comparison of the early outcome of stapled and unstapled techniques of laparoscopic total extraperitoneal inguinal hernia repair. JSLS. Oct-Dec. 2005;9(4):403-7. [pmid: 16381354].
786 Pavlidis TE, Atmatzidis KS, Lazaridis CN, et al. Comparison between modern mesh and conventional non-mesh methods of inguinal hernia repair. Minerva Chir. Feb. 2002;57(1):7-12. [pmid: 11832851].
787 Payne JH Jr, Grininger LM, Izawa MT, et al. Laparoscopic or open inguinal herniorrhaphy? A randomized prospective trial. Arch Surg. Sep. 1994;129(9):973-9. discussion 979-81. [pmid: 8080380].
788 Peeters E, Spiessens C, Oyen R, et al. Laparoscopic inguinal hernia repair in men with lightweight meshes may significantly impair sperm motility: a randomized controlled trial. Ann Surg. Aug. 2010;252(2):240-6. [pmid: 20622657].
789 Picchio M, Lombardi A, Zolovkins A, et al. Tension-free laparoscopic and open hernia repair: randomized controlled trial of early results. World J Surg. Oct. 1999;23(10):1004-7. discussion 1008-9. [pmid: 10512939].
790 Pikoulis E, Tsigris C, Diamantis T, et al. Laparoscopic preperitoneal mesh repair or tension-free mesh plug technique? A prospective study of 471 patients with 543 inguinal hernias. Eur J Surg. 2002;168(11):587-91. [pmid: 12699093].
791 Pokorny H, Klingler A, Schmid T, et al. Recurrence and complications after laparoscopic versus open inguinal hernia repair: results of a prospective randomized multicenter trial. Hernia. Aug. 2008;12(4):385-9. [pmid: 18283518].
792 Pokorny H, Klingler A, Scheyer M, et al. Postoperative pain and quality of life after laparoscopic and open inguinal hernia repair: results of a prospective randomized trial. Hernia. Aug. 2006;10(4):331-7. [pmid: 16819563].
793 Post S, Weiss B, Willer M, et al. Randomized clinical trial of lightweight composite mesh for Lichtenstein inguinal hernia repair. Br J Surg. Jan. 2004;91(1):44-8. [pmid: 14716792].
794 Puccio F, Solazzo M, Marciano P. Comparison of three different mesh materials in tension-free inguinal hernia repair: prolene versus Vypro versus surgisis. Int Surg. Jul-Aug. 2005;90(3 Suppl):S21-3. [pmid: 16463943].
795 Ramshaw B, Shuler FW, Jones HB, et al. Laparoscopic inguinal hernia repair: lessons learned after 1224 consecutive cases. Surg Endosc. Jan. 2001;15(1):50-4. [pmid: 11178763].
796 Ridings P, Evans DS. The transabdominal pre-peritoneal (TAPP) inguinal hernia repair: a trip along the learning curve. J R Coll Surg Edinb. Feb. 2000;45(1):29-32. [pmid: 10815378].
797 Sadowski B, Rodriguez J, Symmonds R, et al. Comparison of polypropylene versus polyester mesh in the Lichtenstein hernia repair with respect to chronic pain and discomfort. Hernia. 2011. Jul. 14. [pmid: 21755316].
798 Sanders DL, Samarakoon DH, Ganshirt SW, et al. A two-centre blinded randomised control study comparing the Lichtenstein patch, Perfix plug and ProLoop plug in the repair of primary inguinal hernia. Hernia. Oct. 2009;13(5):499-503. [pmid: 19644646].
799 Sanjay P, Harris D, Jones P, et al. Randomized controlled trial comparing prolene hernia system and lichtenstein method for inguinal hernia repair. ANZ J Surg. Jul. 2006;76(7):548-52. [pmid: 16813616].
800 Sarli L, Pietra N, Choua O, et al. Laparoscopic hernia repair: a prospective comparison of TAPP and IPOM techniques. Surg Laparosc Endosc. Dec. 1997;7(6):472-6. [pmid: 9438629].
801 Sarli L, Iusco DR, Sansebastiano G, et al. Simultaneous repair of bilateral inguinal hernias: a prospective, randomized study of open, tension-free versus laparoscopic approach. Surg Laparosc Endosc Percutan Tech. Aug. 2001;11(4):262-7. [pmid: 11525372].
802 Schopf S, von Ahnen T, von Ahnen M, et al. Chronic pain after laparoscopic transabdominal preperitoneal hernia repair: a randomized comparison of light and extralight titanized polypropylene mesh. World J Surg. Feb. 2011;35(2):302-10. [pmid: 21103989].
803 Schrenk P, Woisetschlager R, Rieger R, et al. Prospective randomized trial comparing postoperative pain and return to physical activity after transabdominal preperitoneal, total preperitoneal or Shouldice technique for inguinal hernia repair. Br J Surg. Nov. 1996;83(11):1563-6. [pmid: 9014675].
804 Schultz C, Baca I, Gotzen V. Laparoscopic inguinal hernia repair. Surg Endosc. Jun. 2001;15(6):582-4. [pmid: 11591945].
805 Sevonius D, Gunnarsson U, Nordin P, et al. Repeated groin hernia recurrences. Ann Surg. Mar. 2009;249(3):516-8. [pmid: 19247043].
806 Magnusson N, Nordin P, Hedberg M, et al. The time profile of groin hernia recurrences. Hernia. Aug. 2010;14(4):341-4. [pmid: 20340036].
807 Nordin P, Van Der Linden W. Volume of procedures and risk of recurrence after repair of groin hernia: national register study. BMJ. Apr. 26. 2008;336(7650):934-7. [pmid: 18426843].
808 Franneby U, Sandblom G, Nordin P, et al. Risk factors for long-term pain after hernia surgery. Ann Surg. Aug. 2006;244(2):212-9. [pmid: 16858183].
809 Nordin P, Haapaniemi S, Kald A, et al. Influence of suture material and surgical technique on risk of reoperation after non-mesh open hernia repair. Br J Surg. Aug. 1. 2003;90(8):1004-8. [pmid: 12905556].
810 Haapaniemi S, Gunnarsson U, Nordin P, et al. Reoperation after recurrent groin hernia repair. Ann Surg. Jul. 2001;234(1):122-6. [pmid: 11420492].
811 Novik B, Nordin P, Skullman S, et al. More recurrences after hernia mesh fixation with short-term absorbable sutures: A registry study of 82 015 Lichtenstein repairs. Arch Surg. Jan. 2011;146(1):12-7. [pmid: 21242440].
812 Sevonius D, Gunnarsson U, Nordin P, et al. Recurrent groin hernia surgery. Br J Surg. Oct. 2011;98(10):1489-94. [pmid: 21618495].
813 Van Der Linden W, Warg A, Nordin P. National register study of operating time and outcome in hernia repair. Arch Surg. Oct. 2011;146(10):1198-203. [pmid: 22006880].
814 Simmermacher RK, Van Duyn EB, Clevers GJ, et al. Preperitoneal mesh in groin hernia surgery: a randomized trial emphasizing the surgical aspects of perperitoneal placement via a laparoscopic (TEP) or Grid-iron (Ugahary) approach. Hernia. 2000;4:296-8.
815 Singh AN, Bansal VK, Misra MC, et al. Testicular functions, chronic groin pain, and quality of life after laparoscopic and open mesh repair of inguinal hernia: a prospective randomized controlled trial. Surg Endosc. 2011. Nov. 15. [pmid: 22083332].
816 Smith AI, Royston CM, Sedman PC. Stapled and nonstapled laparoscopic transabdominal preperitoneal (TAPP) inguinal hernia repair. A prospective randomized trial. Surg Endosc. Aug. 1999;13(8):804-6. [pmid: 10430690].
817 Staarink M, van Veen RN, Hop WC, et al. A 10-year follow-up study on endoscopic total extraperitoneal repair of primary and recurrent inguinal hernia. Surg Endosc. Aug. 2008;22(8):1803-6. [pmid: 18443875].
818 Sutalo N, Maricic A, Kozomara D, et al. Comparison of results of surgical treatments of primary inguinal hernia with flat polypropylene mesh and three-dimensional prolene (Phs) mesh--one year follow up. Coll Antropol. Mar. Suppl 1. 2010;34:129-33. [pmid: 20402308].
819 Suter M, Martinet O, Spertini F. Reduced acute phase response after laparoscopic total extraperitoneal bilateral hernia repair compared to open repair with the Stoppa procedure. Surg Endosc. Aug. 2002;16(8):1214-9. [pmid: 12189483].
820 Suter M, Martinet O. Postoperative pulmonary dysfunction after bilateral inguinal hernia repair: a prospective randomized study comparing the Stoppa procedure with laparoscopic total extraperitoneal repair (TEPP). Surg Laparosc Endosc Percutan Tech. Dec. 2002;12(6):420-5. [pmid: 12496548].
821 Swadia ND. Laparoscopic totally extra-peritoneal inguinal hernia repair: 9 year's experience. Hernia. 2011. Feb. 3. [pmid: 21290156].
822 Tamme C, Scheidbach H, Hampe C, et al. Totally extraperitoneal endoscopic inguinal hernia repair (TEP). Surg Endosc. Feb. 2003;17(2):190-5. [pmid: 12457220].
823 Taylor C, Layani L, Liew V, et al. Laparoscopic inguinal hernia repair without mesh fixation, early results of a large randomised clinical trial. Surg Endosc. Mar. 2008;22(3):757-62. [pmid: 17885789].
824 Testini M, Lissidini G, Poli E, et al. A single-surgeon randomized trial comparing sutures, N-butyl-2-cyanoacrylate and human fibrin glue for mesh fixation during primary inguinal hernia repair. Can J Surg. Jun. 2010;53(3):155-60. [pmid: 20507786].
825 Torcivia A, Vons C, Barrat C, et al. Influence of mesh type on the quality of early outcomes after inguinal hernia repair in ambulatory setting controlled study: Glucamesh(R) vs Polypropylene(R). Langenbecks Arch Surg. 2010. Nov. 9.
826 Vatansev C, Belviranli M, Aksoy F, et al. The effects of different hernia repair methods on postoperative pain medication and CRP levels. Surg Laparosc Endosc Percutan Tech. Aug. 2002;12(4):243-6. [pmid: 12193818].
827 Vironen J, Nieminen J, Eklund A, et al. Randomized clinical trial of Lichtenstein patch or Prolene Hernia System for inguinal hernia repair. Br J Surg. Jan. 2006;93(1):33-9. [pmid: 16329082].
828 Voitk AJ. The learning curve in laparoscopic inguinal hernia repair for the community general surgeon. Can J Surg. Dec. 1998;41(6):446-50. [pmid: 9854534].
829 Wara P, Bay-Nielsen M, Juul P, et al. Prospective nationwide analysis of laparoscopic versus Lichtenstein repair of inguinal hernia. Br J Surg. Oct. 2005;92(10):1277-81. [pmid: 16003727].
830 Bisgaard T, Bay-Nielsen M, Christensen IJ, et al. Risk of recurrence 5 years or more after primary Lichtenstein mesh and sutured inguinal hernia repair. Br J Surg. Aug. 2007;94(8):1038-40. [pmid: 17607708].
831 Bay-Nielsen M, Perkins FM, Kehlet H, et al. Pain and functional impairment 1 year after inguinal herniorrhaphy: a nationwide questionnaire study. Ann Surg. Jan. 2001;233(1):1-7. [pmid: 11141218].
832 Bay-Nielsen M, Kehlet H. Anaesthesia and post-operative morbidity after elective groin hernia repair: a nation-wide study. Acta Anaesthesiol Scand. Feb. 2008;52(2):169-74. [pmid: 17999709].
833 Bay-Nielsen M, Nilsson E, Nordin P, et al. Chronic pain after open mesh and sutured repair of indirect inguinal hernia in young males. Br J Surg. Oct. 2004;91(10):1372-6. [pmid: 15376186].
834 Bisgaard T, Bay-Nielsen M, Kehlet H. Re-recurrence after operation for recurrent inguinal hernia. A nationwide 8-year follow-up study on the role of type of repair. Ann Surg. Apr. 2008;247(4):707-11. [pmid: 18362636].
835 Wong JU, Leung TH, Huang CC, et al. Comparing chronic pain between fibrin sealant and suture fixation for bilayer polypropylene mesh inguinal hernioplasty: A randomized clinical trial. Am J Surg. Jul. 2011;202(1):34-8. [pmid: 21601822].
836 Zendejas B, Onkendi EO, Brahmbhatt RD, et al. Long-term outcomes of laparoscopic totally extraperitoneal inguinal hernia repairs performed by supervised surgical trainees. Am J Surg. Mar. 2011;201(3):379-83. discussion 383-4. [pmid: 21367383].
837 Zhang H, Lin J, Liao Q, et al. Totally extraperitoneal laparoscopic hernioplasty: the optimal surgical approach. Surg Laparosc Endosc Percutan Tech. Dec. 2009;19(6):501-5. [pmid: 20027096].
838 Zieren J, Zieren HU, Jacobi CA, et al. Prospective randomized study comparing laparoscopic and open tension-free inguinal hernia repair with Shouldice's operation. Am J Surg. Apr. 1998;175(4):330-3. [pmid: 9568665].
839 Zieren J, Zieren HU, Said S, et al. Laparoscopic or conventional groin hernia repair with or without implant. A prospective randomized study. Langenbecks Arch Chir. Suppl II. 1996:609-10. [pmid: 9101947].
840 Haidenberg J, Kendrick ML, Meile T, et al. Totally extraperitoneal (TEP) approach for inguinal hernia: the favorable learning curve for trainees. Curr Surg. Jan-Feb. 2003;60(1):65-8. [pmid: 14972314].