# Evidence Tables

Table 2 Key Questions addressed by included studies

## Key Question 1 Tables

Table 3 Key Question 1: General study information

Table 4 Key Question 1: Patient enrollment criteria related to hernia types

Table 5 Key Question 1: Patient enrollment criteria related to demographics and medical conditions

Table 6 Key Question 1: Patient enrollment criteria, other

Table 7 Key Question 1: Treatment details

Table 8 Key Question 1: Baseline characteristics

Table 9 Key Question 1: Risk of bias assessments

Table 10 Key Question 1: Data

## Key Question 2a Tables

Table 11 Key Question 2a: General study information

Table 12 Key Question 2a: Patient enrollment criteria related to hernia types

Table 13 Key Question 2a: Patient enrollment criteria related to demographics and medical conditions

Table 14 Key Question 2a: Patient enrollment criteria, other

Table 15 Key Question 2a: Treatment details

Table 16 Key Question 2a: Baseline characteristics

Table 17 Key Question 2a: Risk of bias assessments

Table 18 Key Question 2a: Data

## Key Question 2b Tables

Table 19 Key Question 2b: General study information

Table 20 Key Question 2b: Patient enrollment criteria related to hernia types

Table 21 Key Question 2b: Patient enrollment criteria related to demographics and medical conditions

Table 22 Key Question 2b: Patient enrollment criteria, other

Table 23 Key Question 2b: Treatment details

Table 24 Key Question 2b: Baseline characteristics

Table 25 Key Question 2b: Risk of bias assessments

Table 26 Key Question 2b: Data

## Key Question 2c Tables

Table 27 Key Question 2c: General study information

Table 28 Key Question 2c: Patient enrollment criteria related to hernia types

Table 29 Key Question 2c: Patient enrollment criteria related to demographics and medical conditions

Table 30 Key Question 2c: Patient enrollment criteria, other

Table 31 Key Question 2c: Treatment details

Table 32 Key Question 2c: Baseline characteristics

Table 33 Key Question 2c: Risk of bias assessments

Table 34 Key Question 2c: Data

## Key Question 3 Tables

Table 35 Key Question 3: General study information

Table 36 Key Question 3: Patient enrollment criteria related to hernia types

Table 37 Key Question 3: Patient enrollment criteria related to demographics and medical conditions

Table 38 Key Question 3: Patient enrollment criteria, other

Table 39 Key Question 3: Treatment details

Table 40 Key Question 3: Baseline characteristics

Table 41 Key Question 3: Risk of bias assessments

Table 42 Key Question 3: Data

## Key Question 4 Tables

Table 43 Key Question 4: General study information

Table 44 Key Question 4: Patient enrollment criteria related to hernia types

Table 45 Key Question 4: Patient enrollment criteria related to demographics and medical conditions

Table 46 Key Question 4: Patient enrollment criteria, other

Table 47 Key Question 4: Treatment details

Table 48 Key Question 4: Baseline characteristics

Table 49 Key Question 4: Risk of bias assessments

Table 50 Key Question 4: Data

## Key Question 5 Tables

Table 51 Key Question 5: General study information

Table 52 Key Question 5: Patient enrollment criteria related to hernia types

Table 53 Key Question 5: Patient enrollment criteria related to demographics and medical conditions

Table 54 Key Question 5: Patient enrollment criteria, other

Table 55 Key Question 5: Treatment details

Table 56 Key Question 5: Baseline characteristics

Table 57 Key Question 5: Risk of bias assessments

Table 58 Key Question 5: Data

## Key Question 6 Tables

Table 59 Key Question 6: General study information

Table 60 Key Question 6: Patient enrollment criteria related to hernia types

Table 61 Key Question 6: Patient enrollment criteria related to demographics and medical conditions

Table 62 Key Question 6: Patient enrollment criteria, other

Table 63 Key Question 6: Treatment details

Table 64 Key Question 6: Baseline characteristics

Table 65 Key Question 6: Risk of bias assessments

Table 66 Key Question 6: Data

## Key Question 7 Tables

Table 67 Key Question 7: General study information

Table 68 Key Question 7: Patient enrollment criteria related to hernia types

Table 69 Key Question 7: Patient enrollment criteria related to demographics and medical conditions

Table 70 Key Question 7: Patient enrollment criteria, other

Table 71 Key Question 7: Treatment details

Table 72 Key Question 7: Baseline characteristics

Table 73 Key Question 7: Risk of Bias Assessments

No risk of bias table for this key question because risk of bias was not formally assessed for this key question.

Table 74 Key Question 7: Data

## Key Question 8 Tables

There are no evidence tables for this Key Question because no studies met the inclusion criteria.

## Key Question 9 Tables

Table 75 Key Question 9: General study information

Table 76 Key Question 9: Patient enrollment criteria related to hernia types

Table 77 Key Question 9: Patient enrollment criteria related to demographics and medical conditions

Table 78 Key Question 9: Patient enrollment criteria, other

Table 79 Key Question 9: Treatment details

Table 80 Key Question 9: Baseline characteristics

Table 81 Key Question 9: Risk of bias assessments

Table 82 Key Question 9: Data